# References

1 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
2 Wiebe N, Vandermeer B, Platt RW, Klassen TP, Moher D, Barrowman NJ. A systematic review identifies a lack of standardization in methods for handling missing variance data. J Clin Epidemiol. 2006;59:342-53. [pmid: 16549255].
3 Cauchy A. Oeuvres complètes d'Augustin Cauchy, 2, III. Paris. Gauthier-Villars et fils. 1821:373. visualiseur.bnf.fr/CadresFenetre?O=NUMM-90195&I=377&M=tdm. August 30, 2012.
4 Schwarz HA. Über ein Flächen kleinsten Flächeninhalts betreffendes Problem der Variationsrechnung, Acta Societatis Scientiarum Fennicae XV: 318. Helsinki. Societas litterariae fennicae. 1888. www-stat.wharton.upenn.edu/∼steele/Publications/Books/CSMC/Schwarz.pdf. August 30, 2012.
5 Burton A, Altman DG, Royston P, Holder RL. The design of simulation studies in medical statistics. Stat Med. 2006;25:4279-92. [pmid: 16947139].
6 Jackson D, Bowden J, Baker R. How does the DerSimonian and Laird procedure for random effects meta-analysis compare with its more efficient but harder to compute counterparts?. Journal of Statistical Planning and Inference. 2010;140:961-70.
7 Viechtbauer W. Bias and efficiency of meta-analytic variance estimators in the random-effects model. Journal of Educational and Behavioral Statistics. 2005;30:261-93.
8 Brockwell SE, Gordon IR. A comparison of statistical methods for meta-analysis. Stat Med. 2001;20:825-40. [pmid: 11252006].
9 Follmann D, Elliott P, Suh I, Cutler J. Variance imputation for overviews of clinical trials with continuous response. J Clin Epidemiol. 1992;45:769-73. [pmid: 1619456].
10 Hozo SP, Djulbegovic B, Hozo I. Estimating the mean and variance from the median, range, and the size of a sample. BMC Med Res Methodol. 2005;5:13. [pmid: 15840177].
11 Donders AR, van der Heijden GJ, Stijnen T, Moons KG. Review: a gentle introduction to imputation of missing values. J Clin Epidemiol. 2006;59:1087-91. [pmid: 16980149].