# Methods

## Source of Studies

We collected continuous outcome data from a convenience sample of RCTs from three large sets of published and unpublished studies. Our initial goal was to identify at least 100 comparative studies with sufficient data (see third bullet under Study Eligibility below). The first source included all primary studies (studies with reported data) we had available as full-text articles stored on our Evidence-based Practice Center's (EPC) network (studies on a wide range of domains including, but not limited to, cardiology, dentistry, gastrointestinal disease, maternal health, nutrition, oncology, pediatrics, pharmacogenetics, pulmonology, and surgery). The second source included all full-text primary studies stored on the network of the Evidence Review Team for the evidence-based clinical practice guideline organization Kidney Disease: Improving Global Outcomes (KDIGO); these included studies retrieved for 19 guidelines and several other topics. The third source was the ClinicalTrials.gov database. With the assistance of our colleagues at the National Library of Medicine, we compiled a list of 1,433 records of trials with published results as of October 2011.

## Study Eligibility

The full-text (or spreadsheet from ClinicalTrials.gov) of each study was screened with the following eligibility criteria:

- Randomized or nonrandomized prospective comparative studies of parallel or crossover design (with two or more study groups [arms]); crossover studies had to report eligible data for the baseline and final timepoints in the first phase of the crossover (i.e., the parallel group phase prior to crossover)
- One or more continuous outcomes reported
- Sufficient data to back-calculate the correlation value, r, in each study group, including all three sets of items here:
- Mean baseline estimate and a measure of its variation (SE, standard deviation, or defined confidence interval)
- Mean final estimate and a measure of its variation (SE, standard deviation, or defined confidence interval)
- Within-group change (final minus baseline) and a measure of its variation (SE, standard deviation, or defined confidence interval)
- All data had to be reported with the same metrics; in particular we excluded studies that reported only baseline values and percent changes from baseline values
- All data had to be reported in text format (i.e., we did not estimate data from figures)
- In addition,
  ○ We excluded median values, interquartile ranges, full ranges, and P values. For the purposes of this exercise, we considered P values to be an insufficiently accurate estimate of the within-group SE for calculating r. We initially planned to include studies that reported exact P values with at least 2 significant digits (e.g., 0.75 or 0.0036), however, we decided that large P values were not sufficiently precise to accurately estimate r and we were also concerned that the large majority of potentially eligible studies (based on P value) had highly statistically significant within-group differences and thus their inclusion might lead to a biased selection of studies.
  ○ We excluded within-group or between-group differences that were adjusted for baseline covariates.

Of note, we included studies of any population, intervention, comparator, or (continuous) outcome.

## Data Extraction

From each study we extracted the following data:

- Study identifier information (including PubMed identifiers for associated studies reported in ClinicalTrials.gov)
- Medical domain of the study and a brief summary of the eligibility criteria
- Study design (RCT, prospective nonrandomized comparative study)
- Followup duration
  ○ When outcomes were reported at multiple followup timepoints, we extracted data from the last timepoint when >80 percent of the baseline sample size were included; if no timepoint met this criterion we used the timepoint with the largest sample size
- Names of interventions, including comparator, for up to three interventions
  ○ If there were more than three interventions (study groups), we included the comparator intervention (e.g., placebo, usual care) and the first two other interventions listed
- Names and units of up to five continuous outcomes
  ○ If there were more than five continuous outcomes reported, we randomly selected five outcomes (using Excel's random number generator); however, we tried to avoid extracting outcomes that were derivative of other included outcomes (e.g., mean arterial blood pressure and systolic and diastolic blood pressures)
- For each outcome-intervention pair we extracted
  ○ Baseline, final, and difference sample sizes
    ■ If final and difference sample sizes were not reported, we assumed they were the same as the baseline sample size
    ■ If difference sample size was not reported, we assumed it was the same as the final sample size
  ○ Baseline, final, and difference reported mean values
  ○ Baseline, final, and difference reported variation (either SE, standard deviation, or confidence interval, but not P value)

Of note, for articles that reported multiple trials, we extracted each trial separately.

Each study was extracted by one researcher (EB, AE, KP). The extractors included the lead investigator who has more than 10 years of experience with data extraction and two research associates with 3 and 7 years, respectively, of experience with data extraction. After all extractions were complete, each extraction was reviewed and corrected by a second researcher. The lead investigator extracted or reviewed a large majority of the eligible studies. Studies or outcomes that did not meet eligibility criteria were deleted. The PubMed identification numbers were compared and duplicate studies were consolidated.

For each intervention-outcome pair, we calculated the value of r based on the reported data.

## Data Analyses

### Aim 1 Empirical Assessment

We first excluded study groups where the estimated (back-calculated) correlation coefficient between baseline and final values was outside the interval [-1, 1]; such estimates of the correlation coefficient are not valid^b^ and occur because of rounding of values reported (or errors) in published papers. We used our best judgment to categorize outcome types as a device measures (e.g., tonometry), laboratory values, signs (e.g., visual acuity), symptoms (e.g., pain), questionnaire or equivalent scores, or “other.” Of note, blood pressure (clinic, home, or ambulatory) was categorized as a device measure. Similarly, we classified studies into clinical domains based on a combination of the study eligibility criteria and the goal of treatment; studies could be classified with multiple clinical domains (e.g., kidney disease and cardiovascular disease). We also categorized interventions (study groups) as either active or no treatment (including placebo and usual care).

b The correlation coefficient can be shown to have range=[-1, 1] because of the Cauchy–Schwarz inequality.3,4

We calculated basic summary statistics for the range of calculated r values. We drew scatterplots with locally weighted smoothing lines (LOWESS), histograms, and boxplots of the r values against different study or outcome characteristics, and sample size. Associations between r values and continuous study characteristics (e.g., study duration) were expressed as Spearman correlation coefficients; comparisons of correlation values across categorical characteristics (e.g., active treatment versus no treatment) were analyzed with the Kruskall-Wallis test.

To assess what study or group characteristics affect the within-group correlation we used a mixed effects linear model with the Fisher z-transformed^c^ correlation coefficient as the outcome of interest and the following predictors: duration of followup (square root transformed to improve visualization of short-duration followup), type of intervention (active treatment or no treatment), group sample size (ln-transformed), outcomes measured, and clinical domain (for analysis in the model, we used our judgment to choose the dominant clinical domain for the four studies assigned multiple clinical domains). This model accounted for the clustering of study groups within studies using a random intercept by study. We used the same model to test if there was an interaction between study duration or baseline sample size and type of treatment on the reported correlation by including appropriate cross-product terms (study duration × type of treatment, or baseline sample size × type of treatment, respectively).

c The Fisher z-transformation of variable r is z ( r ) = (1)/(2) ln ( (1 + r)/(1 − r) ) = atanh ( r ) . This is a variance-stabilizing transformation for the estimated correlation coefficient. Atanh = inverse hyperbolic tangent

All analyses were performed in Stata version IC/12.1 (Stata Corp., College Station, TX). Statistical significance was defined as a two-sided P-value<0.05 for all comparisons. No adjustments for multiple comparisons were performed.

### Aim 2 Impact of Imputing Alternative Correlation Values in the Empirical Dataset

To assess the effect of imputing correlation values on the empirical dataset, we recalculated the study-specific SEs of the within-group change for each study group using alternative imputed values (ρ=0, 0.25, 0.50, and 0.75). The tested imputed values are commonly used in sensitivity analyses of studies included in meta-analyses that do not report the within-group correlation value. We graphically compared SEs calculated using imputed values against SEs calculated using the complete (true) data by constructing pairwise scatterplots.

To analyze the effect of imputing various correlation values on the SEs of net changes (the study estimates most likely to be used in meta-analyses), for each study we also paired the comparator group with an arbitrarily selected active intervention (if there was no obvious comparator, we arbitrarily selected two interventions). These data were analyzed in the same manner as within-group correlation values.

### Aim 3 Imputing Correlation Values on Fixed and Random Effects Model Meta-Analyses

To explore the analytical performance of imputing within-group correlation values when some or all studies in a meta-analysis do not report the necessary estimates, we performed a series of simulation studies. Details about the simulation methods and parameter values are presented in Appendix A. Briefly, we simulated meta-analyses (each including 5, 10, or 20 studies, all of which had the same sample size) of parallel-group design trials with two treatment groups and a continuous outcome, measured at baseline and followup. For parsimony, we assumed that the study groups were independent, all patients remained in their treatment assignment group (intention-to-treat), and they had complete followup. Table 1 summarizes the parameter values used in simulations. We evaluated different control group sample sizes and different randomization ratios (sample size ratios between the treated and control group of 1:1 or 2:1). Values for the baseline and followup outcome values were drawn from bivariate normal distributions. The within-group correlation was assumed to be the same for both groups; we assessed correlation values equal to the 25^th^, 50^th^, and 75^th^ percentile of the distribution of correlation values obtained in the empirical component of this study (Aim 1), along with the special case of no correlation (r=0). The mean of the baseline values of treated and control groups and the followup values of the control group were assumed to be zero; the variance for these values was set at 1 SE unit. The followup mean of the treated group depended on the treatment effect (0, 0.1, 0.5, and 1). The followup variance of the treated group was assumed to be either 1 or 2. The treatment effect was assumed to be fixed (shared across studies) for some scenarios and variable (i.e., a random quantity) in others. We also explored different levels of variability of treatment effects (i.e., the between-study heterogeneity; τ-squared=0, 0.1, or 0.5). For each scenario we simulated 1,000 meta-analyses (i.e., 5,000, 10,000, and 20,000 studies when the number of studies per meta-analysis was 5, 10, or 20 respectively).

Table 1 Simulation parameters and values used^*^

Parameters | Simulation Values | Number of Scenarios
Control and treatment groups baseline means | 0 | 1
Control and treatment groups baseline variances | 1 | 1
Control group followup mean | 0 | 1
Control group followup variance | 1 | 1
Average treatment followup mean (treatment effect) | 0 or 0.1 or 0.5 or 1 | 4
Treatment group followup variance | 1 or 2 | 2
Control group within-group correlation^†^ | 0 or 0.40 or 0.59 or 0.81 | 4
Treatment group within-group correlation | Set equal to the control group | 1
Control group sample size | 20 or 50 or 100 | 3
Sample size ratio (treatment:control) | 1 or 2 | 2
Between-study heterogeneity of the treatment effect (τ-squared) | 0 or 0.1 or 0.5 | 3
Number of studies per meta-analysis | 5 or 10 or 20 | 3
Total scenarios | - | 1,728

* See Appendix A for additional details on the simulation model.

† Chosen values based on the empirical values from Aim 1 (25^th^, 50^th^, and 75^th^ percentiles, and 0).

#### Meta-Analysis Methods

For each simulation scenario we performed meta-analyses using fixed and random effects inverse variance models. For random effects analyses the between-study variance (heterogeneity) was estimated using the DerSimonian-Laird method.1 We considered three types of scenarios for the analysis of the simulated data, to reflect different levels of reporting across studies:

1. Availability of “complete data” from all studies, including the correlation of the baseline and followup values in each study group. This reflects a “best case” scenario for meta-analysis based on aggregate data: all studies report adequate data for synthesizing net change values, while accounting for the correlation of baseline and followup measurements in each study group.
2. Availability of “incomplete data” from all studies, i.e. missing correlation values for all studies (both treatment and control groups). This reflects the worst case scenario in meta-analyses of published data: none of the included studies provide sufficient statistics to estimate the net change and values need to be imputed for all studies. Commonly, a value of 0.5 is used; however, sensitivity analysis using different correlation values may be performed. We present results under all 1,728 scenarios using an imputation value of 0.5. For a typical scenario we also show results for different imputed values. Because the results follow a predictable pattern (see Discussion), we do not present results for other scenarios.
3. Availability of “partially complete data,” i.e. missing correlation values from some of the included studies. This represents an intermediate case where only some of the studies report adequate data to calculate sufficient statistics whereas the within-arm correlations need to be imputed for the rest. To emulate this scenario, we generated datasets where the within-arm correlation values were missing from both the treatment and control groups from 50 percent of the studies included in each meta-analysis.

##### Comparisons Between Imputation Methods

We summarized the simulation results using graphs and tables. We focus on the following measures of performance.5

a. Bias: the deviation of the summary estimates (treatment effects) obtained by using imputed correlation values compared with the simulated true parameter value.
b. Coverage: the proportion of times the obtained 95% confidence interval (from the meta-analysis of simulated studies) contains the simulated true parameter value (treatment effect).
c. Accuracy: the mean squared error (the sum of the variance and the squared bias) of the simulation.

For brevity, in the main text of the report we present results from random effects meta-analyses for all simulated magnitudes of the treatment effect, under homogeneity and different levels of heterogeneity (between-studies), and for all control group sample sizes. However, we restrict the results presented to cases where the sample size of the treatment and control groups were equal, and the baseline and followup treatment variances in the treatment group were equal. Scenarios with unequal treatment group variances (variance ratio=2) and unbalanced treatment and control groups (sample size ratio=2) produced very similar results and are summarized in Appendix B

Throughout the report, we emphasize the impact of imputing correlation values on estimates of the treatment effect and its uncertainty. We do not expand on the inherent properties of the meta-analytic summary estimates, although we highlight key relevant findings. The performance of the common meta-analytic estimates used in our analyses is generally well-understood and has been extensively explored in a number of theoretical papers and simulation studies.1,6-8