# Introduction

When conducting meta-analyses of continuous outcomes (for example, fasting blood glucose, systolic blood pressure) in randomized clinical trials (RCTs) it is common that studies do not report sufficiently complete data. For most meta-analyses of parallel design trials, the parameter of interest is the between-group difference in the change of the continuous outcome; namely the “net difference” between the change in outcome in the intervention group (A) minus the change in the control group (B): ΔNetChange = (change_A_) − (change_B_), or equivalently ΔNetChange = (Final_A_ − Baseline_A_) − (Final_B_ − Baseline_B_).

For inverse-variance meta-analysis of such trials, the net change and the variance (or standard error [SE]) of the net change are needed from each trial.1 In general, the net change is readily available or can be easily calculated from published trial reports. It is common, though, that studies do not report the SE of the net change (or appropriate statistics that can be used to calculate it, such as the standard deviation of the net change, its confidence interval, or the exact P value comparing baseline and post-treatment values). If a study reports the SEs for the change from baseline in both the intervention and control groups, then it is possible to accurately calculate the SE of the net change: SE_NetChange_ = sqrt(SE_A_^2^ + SE_B_^2^) , where SE_A_ and SE_B_ are the SE of the change in the outcome for each trial group.

However, many studies do not report SE data for the within-group changes. Instead, they commonly report the SE (or standard deviation) for both the baseline and the final values within each group. In such cases, for meta-analysis, one must estimate the SE of the within-group changes. Because the baseline and final values are calculated on the same patients they are correlated and the SE of the within group change in each group is given by the formula: SE_change within arm_ = sqrt(SE_Final_^2^ + SE_Baseline_^2^ − 2 × r × SE_Final_ × SE_Baseline_) , where r is the correlation between baseline and final values. All correlations nominally take values between –1 and 1. If r is positive, within the context of a given study, participants with high baseline values tend to have high final values relative to other participants (and vice versa). If r=0, baseline and final values are independent of each other. If r is negative, participants with high baseline values tend to have low final values (and vice versa). The closer r is to 1 (or –1), the stronger the prediction of final values from the baseline values. Negative within-group correlations are likely to be uncommon, so that, in the majority of studies reporting baseline and final measurements, one expects the correlations to be positive.^a^

a However, this is to be verified empirically

Thus, in the common scenario where the SE of within-group changes (or its equivalent) is not reported (and not available from the study authors), the meta-analyst must make a best guess (or a series of guesses) at the value of r to calculate the net-change SE for the study. Other options for the meta-analyst, which are not further discussed, include excluding the study from the meta-analysis or using an SE that is based on the standard deviations of other studies included in the meta-analysis—or from other sources of studies (e.g., the median or largest standard deviation among included studies). Many authors use the arbitrarily chosen value of r=0.5, presumably because it is half way between 0 and 1. An empirical assessment of meta-analytic practices described large variation in handling missing variance data in systematic reviews. Among 101 systematic reviews in an empiric assessment by Wiebe et al.,2 29 imputed within-arm correlations. Approaches included imputing a correlation value of 0.5, a value of 0, using a value from another included study (the most common approach), performing a sensitivity analysis using at least two values, or imputing an unstated value.

Clearly, there is little evidence to recommend a specific approach for meta-analysis of net-changes when some of the within-group correlations are missing. Therefore, we set out to better understand the distribution of true values of r across published trials, to assess if there are any associations between characteristics of the trials and the value of r, and how using different values of r in meta-analyses might affect summary estimates.

## Study Aims

1. In a representative sample of trials, describe the range of correlation values, r.
2. In a representative sample of trials, compare values of the net-change SEs derived from reported within-group SEs with the net-change SEs derived from estimating the correlation values, r.
3. By simulation, explore the impact of imputing a range of correlation values, r, on fixed and random effects model meta-analyses.