# Discussion

The net difference in the change from baseline is a frequently used metric in meta-analysis of continuous outcomes, but statistics sufficient for meta-analysis are commonly reported only incompletely. Specifically, the variance of this metric is often not possible to calculate with algebraic computations, because the within-arm correlations are not reported. Imputing the missing correlations (and by extension the missing variances) is arguably preferable to excluding the respective studies from the meta-analysis.2,9,10 We report the empirical distribution of within-arm correlation coefficients from a large number of studies where such information was algebraically extractable. We also explored the effects of imputing a range of values for the correlation coefficient in a simulation analysis. To our knowledge, this analysis is the first such exploration of real-life within-group correlations and of the effect of imputing different correlations in meta-analyses. While we analyzed a large body of comparative studies, we acknowledge that studies available to us from our previous systematic reviews and from ClinicalTrials.gov may not be completely representative of studies encountered in a typical systematic review. In particular, nephrology studies are overrepresented in our empirical dataset. Nevertheless, it appears unlikely that our included studies were a biased sample of studies that report adequate data to estimate within-group correlation. However, it is plausible that, in general, studies that report all data for baseline, final, and change values may be inherently different (biased) compared with studies that fail to report change data. This latter possibility, however, cannot be tested from the reported data. It remains a possibility, though, that our findings of typical correlations in studies could deviate from the true range of correlations in studies with missing data.

The main limitation to a determination of actual correlation values in published studies is the inherent error involved in back-calculating correlation values from imprecise reported standard deviations or standard errors (SEs). The fact that 5 percent of calculated values were implausible (outside the bounds of -1 to +1) indicates that data extracted from publications may not always be accurate or sufficiently precise due to rounding errors. However, there is no reason to think that our estimates were biased toward under- or over-estimating correlation values. Furthermore, while we covered many scenarios in our simulations, a large number of other scenarios could have been investigated (including using random-effects models different than DerSimmonian and Laird, using different values of ρ for treated and untreated arms, and using numerous other imputed values of r). However, we believe that our simulations cover the range of greatest interest to applied meta-analyses.

We evaluated 811 within-group correlation values from 123 studies with 281 study groups. As expected, the vast majority (96%) were positive. For most realistic clinical scenarios, baseline and final measurements in the same individual will tend to be similar (be positively correlated with each other). We have not identified a realistic scenario where, in contrast, one would expect baseline and final values to be negatively correlated (i.e., r<0), though such scenarios may very well be possible. There are several possible explanations for the few negative correlations in our empirical sample. First, they are sample estimates of unobserved true correlation coefficients, but because of random variation they have negative values, even though the true correlations were not negative. Second, our calculations assumed normal distributions (when extracting data from individual studies), which may be ill-justified for some studies. Third, some may correspond to clinical scenarios where one would expect a negative correlation between baseline and final measurements, although on inspection of the database we did not recognize such a scenario. Finally, we derived the correlation estimates using algebraic calculations from quantities reported in the papers, and thus reporting inconsistencies, rounding errors, or other mistakes in the papers themselves may also play a role. Our best guess is that this latter reason explains most of the instances of estimated negative correlation. These studies (4% of the total), together with the 5 percent of studies with estimates of r outside the range [-1, 1], which are clearly due to rounding or reporting errors, suggest that poor estimates of r are common, even among the studies with seemingly reasonable estimates (the 91% overall with estimates of r between 0 and 1).

We describe variation in the distribution of the within-group correlation values by the characteristics of the outcomes, the interventions, and the studies. For example, on average, correlation values were higher in control (no treatment) study groups with no active intervention compared with study groups with active interventions. This is expected, as an intervention introduces an additional variance component (related to the variability of the treatment effect), reducing the observed within-group correlation in treated groups. It might not be unreasonable to impute a lower correlation value for the treatment group than for the no treatment group within a study, although there was substantial heterogeneity in the estimated within-arm correlations among both active intervention and no treatment study arms. In addition, the distributions of correlation values overlapped substantially between active and no treatment arms. Thus, the use of differential imputation of correlation values in study groups may be overkill. Similarly, though we found differences in correlation values across different clinical domains and different outcome types, we do not believe this analysis supports imputing different correlation values for different clinical domains or outcomes. It should be noted that any categorization of clinical domains and outcome types is arbitrary and imperfect but our sample size was much too small to closely investigate specific clinical domains and outcomes. Overall, we would not recommend selecting an imputation value (e.g., from a regression) using the characteristics of the outcome, the study group, and the study as predictors. Our sampling scheme was based on convenience of accessing the information of interest, and many types of outcomes, diseases, interventions and populations were not included. Therefore, predictions from regression models built in this sample are probably not generalizable. Finally, although randomized crossover studies were not the focus of this report, our recommendations should be largely applicable to such studies as well.

So how should meta-analysts go about imputing the missing correlations? Our simulation studies indicate that the choice of imputed correlation value primarily affects the coverage probabilities of the final meta-analysis estimate, rather than its bias. In other words, the choice of imputed r value affects the probability that the “true” estimate falls within the 95 percent confidence interval of the summary estimate, but is unlikely to bias the summary estimate in one direction or the other. The absence of bias is expected because: (1) the correlation of baseline and final values is not used in the calculation of the study-specific effect size; and (2) the variance of the study specific effect size (and, consequently, the corresponding weight) is not dependent on its value in the case of meta-analysis of continuous outcomes. Thus, even though the imputation of missing correlation values is bound to affect the weights of the study specific point estimates (because it affects the SE of the net change), it does not introduce bias in the estimate of the treatment effect. However, the farther the imputed correlation value is from the (unknown) true value, the larger the impact on the coverage probability of the meta-analysis estimate. Imputing a larger-than-true value results in smaller study variances, and imputing a lower-than-true value results in larger study variances. Even so, the effect on the coverage probabilities is relatively small, and arguably inconsequential for many meta-analyses. Although not the focus of the current paper, our simulations demonstrated that fixed effects meta-analysis has poor coverage when the data are derived from truly heterogeneous studies. The DerSimonian-Laird method had much better performance, even though its coverage probability in the presence of moderate to severe heterogeneity was also lower than nominal when the number of studies was small. Suboptimal coverage with increasing between-study heterogeneity has been reported in previous simulation studies of the DerSimonian-Laird method.6-8 Iterative estimators of between-study heterogeneity have better performance in the presence of such extreme heterogeneity.

Based on the above, including our finding of a median correlation value across studies of 0.59 and our simulations of meta-analyses with convenience correlation value estimates of 0.25, 0.5, and 0.75, we propose the following algorithm for meta-analyses of continuous outcomes where the net difference in the change from baseline is the metric of choice, and within-arm correlation values require imputation due to insufficiently reported data (Table 4). Follman et al. (1992) also proposed using 0.5 as the “default” imputed value, on the basis of statistical efficiency.9 We acknowledge that imputation of a “fixed” number ignores the uncertainty of the imputed value. Nonetheless, in typical meta-analysis applications (where the number of included studies is small and with limited covariate information) theory-motivated approaches, such as multiple imputation, are unlikely to be of practical use.11 Furthermore, verifying the assumptions underlying such methods (e.g., that data are missing at random) is probably impossible in retrospective (i.e., literature-based) meta-analyses.

Table 4 Proposed algorithm for handling studies with missing data for standard error of the net change

Step^*^ | Description | Comment or rationale | Strength^†^ [High/Low]
1 | Include all studies in the main analysis by imputing missing within-group correlations | Maximizes use of available information When only the within-group correlation is missing, the within-group variance can still be estimated within an interval. This partial information should not be discarded In most cases, the optimal imputation value will be unknowable. | High
2^‡^ | If a majority of studies report within-group correlations, use the median correlation as a main analysis. | This empirical imputation is arbitrary, as there is no guarantee that studies requiring imputation would have similar values. Choosing the lowest observed positive correlation, or the 25^th^ percentile of the observed correlations results in greater study variances and thus lower weights in a meta-analysis. However, we see no particular reason to favor any particular percentile (e.g., median versus 25^th^ percentile) | Low^§^
3 | If a majority or all studies do not report within-group correlations, and in the absence of other relevant data, impute a value of 0.5 to 0.6 for the main analysis. An alternative is to impute a value of about 0.5-0.6 for treatment groups and about 0.75 for no treatment groups. | The median value in the empirical sample was 0.59. The median value in the empirical sample of active treatment groups was 0.54 and of no treatment groups was 0.73. Being in the middle of the domain of values for positive correlations, imputed values of 0.5 to 0.6 minimizes the difference from the unknown true value, and thus the effect on the coverage probability of the meta-analysis estimate For most real-life scenarios we expect non-negative within-group correlations We see no argument in favor of using different correlation values for each study | Low
4 | Perform sensitivity analyses for a range of plausible values | In our simulation studies imputing a value of 0.5 has a small effect on coverage probabilities (and no effects on bias) over a wide range of scenarios. We conjecture that most often sensitivity analyses will not change meta-analysis conclusions. Reasonable to include 0 as the lower bound. In the absence of external information, the upper bound could be 0.8 (75th percentile in our empirical sample) | Low∥

* Step 1 should be done in all cases where meta-analyses of net-changes are performed. Steps 2 to 4 should be considered in order of preference.

† High strength: Failure to follow recommendation may result in substantial bias. Low strength: Choice of whether recommendation is followed is unlikely to alter or bias the meta-analysis. This strength scale was developed by the authors and is arbitrary. We expect it to be described more fully in a forthcoming article.

‡ In place of step 2, others have proposed the use of multiple imputation, if the meta-analysis has a large number of studies and a majority of them report the correlation.

§ This step has face validity, but was not addressed in this report. It is also proposed by Wiebe et al.2

∥ This is good practice, but failure to perform sensitivity analyses will likely not result in misleading conclusions.