# Included Studies

Articles 1–66 are from ClinicalTrials.gov. Articles 67–127 are from Tufts' network drives from previous systematic reviews.

1 Alexandre B. Comparison of Insulin Detemir and NPH Insulin Given Once Daily in Ageing Subjects With Type 2 Diabetes (3L). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00506662?term=NCT00506662&rank=1 NLM Identifier: NCT00506662. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
2 Astellas Pharma Canada I. Assess the Efficacy and Safety of Alefacept With Narrow Band Ultraviolet B Phototherapy (nbUVB) vs. Alefacept Alone in Chronic Plaque Psoriasis Subjects. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00658606?term=NCT00658606&rank=1 NLM Identifier: NCT00658606. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
3 Astellas Pharma Canada I. Canadian Cardiology de Novo Study: A Comparison Between Tacrolimus- and Cyclosporine- Based Immunoprophylactic Regimens. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00157014?term=NCT00157014&rank=1 NLM Identifier: NCT00157014. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
4 Astellas Pharma Canada I. As. Study to Compare the Safety and Efficacy of Solifenacin With Oxybutynin for the Treatment of Overactive Bladder (VECTOR). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00431041?term=NCT00431041&rank=1 NLM Identifier: NCT00431041. 2012. Bethesda. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
5 Astellas Pharma Global Development. Safety/Efficacy of Induction Agents With Tacrolimus, MMF, and Rapid Steroid Withdrawal in Renal Transplant Recipients (INTAC). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00113269?term=NCT00113269&rank=1 NLM Identifier: NCT00113269. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
6 Astellas Pharma Global Development. A Study of the Safety and Tolerance of Regadenoson in Subjects With Asthma or Chronic Obstructive Pulmonary Disease. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00862641?term=NCT00862641&rank=1 NLM Identifier: NCT00862641. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
7 Astellas Pharma US I. A Study of the Safety and Tolerance of Regadenoson in Subjects With Asthma or Chronic Obstructive Pulmonary Disease. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00862641?term=NCT00862641&rank=1 NLM Identifier: NCT00862641. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
8 Astellas Pharma US I. Study of Efficacy & Safety for 3 Infusion Regimens of IV Conivaptan in Subjects With Euvolemic or Hypervolemic Hyponatremia. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00478192?term=NCT00478192&rank=1 NLM Identifier: NCT00478192. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
9 Astellas Pharma US I. Study of VESIcare® In Overactive Bladder (OAB) Subjects to Evaluate Symptom Bother and Health Related Quality of Life (VIBRANT). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00573508?term=NCT00573508&rank=1 NLM Identifier: NCT00573508. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
10 BioMarin Pharmaceutical. Study to Evaluate the Safety and Efficacy of Phenoptin™ in Subjects With Phenylketonuria Who Have Elevated Phenylalanine Levels. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00104247?term=NCT00104247&rank=1 NLM Identifier: NCT00104247. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
11 Brunetta P. A Study to Evaluate the Efficacy and Safety of Rituximab in Patients With Severe Systemic Lupus Erythematosus (EXPLORER). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00137969?term=NCT00137969&rank=1 NLM Identifier: NCT00137969. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
12 Decker C. A Phase 4 Two Dose Level Study of Naglazyme(TM) (Galsulfase) in Infants With MPS VI. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00299000?term=NCT00299000&rank=1 NLM Identifier: NCT00299000. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
13 Dyax Corp. Efficacy and Safety Study of DX-88 to Treat Acute Attacks of Hereditary Angioedema (HAE). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00262080?term=NCT00262080&rank=1 NLM Identifier: NCT00262080. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
14 Eli Lilly and Company. Hemodynamic and Perfusion Response to Drotrecogin Alfa (Activated) in Patients With Septic Shock. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00279214?term=NCT00279214&rank=1 NLM Identifier: NCT00279214. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
15 Eli Lilly and Company. Comparison of Two Basal Insulins for Patients With Type 2 Diabetes (IOOY). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00494013?term=NCT00494013&rank=1 NLM Identifier: NCT00494013. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
16 Eli Lilly and Company. Evaluate Protein C Levels in Severe Sepsis Patients on Drotrecogin Alfa (Activated). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00386425?term=NCT00386425&rank=1 NLM Identifier: NCT00386425. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
17 Eli Lilly and Company. Comparison of Two Basal Insulin Therapies for Patients With Type 1 Diabetes (IOOZ). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00487240?term=NCT00487240&rank=1 NLM Identifier: NTC00487240. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
18 Eli Lilly and Company. Atomoxetine to Treat Korean Children and Adolescents With Attention-Deficit/Hyperactivity Disorder (ADHD). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00568685?term=NCT00568685&rank=1 NLM Identifier: NCT00568685. 2012. Bathesda. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
19 Evans R. Rilonacept for Treatment of Cryopyrin-Associated Periodic Syndromes (CAPS). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00288704?term=NCT00288704&rank=1 NLM Identifier: NTC00288704. 2012. Bethesda. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
20 Fujii A. Curosurf and Survanta Treatment(CAST)of RDS in Very Premature Infants. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00767039?term=NCT00767039&rank=1 NLM Identifier: NCT00767039. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
21 Genzyme. A Placebo-Controlled Study of Safety and Effectiveness of Myozyme (Alglucosidase Alfa) in Patients With Late-Onset Pompe Disease. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00158600?term=NCT00158600&rank=1 NLM Identifier: NCT00158600. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
22 Genzyme. Clinical Study of Aldurazyme in Patients With Mucopolysaccharidosis (MPS) I. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00912925?term=NCT00912925&rank=1 NLM Identifier: NCT00912925. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
23 Genzyme Coorporation. A Study of the Safety and Efficacy of Fabrazyme (Agalsidase Beta) as Compared to Placebo in Patients With Advanced Fabry Disease. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00074984?term=NCT00074984&rank=1 NLM Identifier: NCT00074984. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
24 GSK Clinical Trials. Rosiglitazone Versus a Sulfonylurea On Progression Of Atherosclerosis In Patients With Heart Disease And Type 2 Diabetes. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00116831?term=NCT00116831&rank=1 NLM Identifier: NCT00116831. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
25 GSK Clinical Trials. A 12-Week Study To Assess The Safety Of Fluticasone Propionate/Salmeterol 100/50 HFA Versus Fluticasone Propionate 100 HFA In Children With Asthma. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00441441?term=NCT00441441&rank=1 NLM Identifier: NCT00441441. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
26 GSK Clinical Trials. A 16-Week Study to Evaluate the Effect of Advair DISKUS™ 250/50mcg on Arterial Stiffness in Subjects With Chronic Obstructive Pulmonary Disease (COPD). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00857766?term=NCT00857766&rank=1 NLM Identifier: NCT00857766. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
27 GSK Clinical Trials. Influence Of Salmeterol Xinafoate/Fluticasone Propionate (50/500 μg BID) On The Course Of The Disease And Exacerbation Frequency In COPD Patients Gold Stage III And IV. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00527826?term=NCT00527826&rank=1 NLM Identifier: NCT00527826. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
28 GSK Clinical Trials. A Study to Determine the Effect of Sumatriptan and Naproxen Sodium Combination Tablet, Sumatriptan Tablet, and Naproxen Sodium Tablet on Blood Pressure When Treating Migraine Headaches That Occur During a 6-month Period. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00792636?term=NCT00792636&rank=1 NLM Identifier: NCT00792636. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
29 GSK Clinical Trials. A Study To Assess The Efficacy And Safety Of Dutasteride 05mg Once Daily For 6 Months In The Treatment Of Male Subjects With Androgenetic Alopecia. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00441116?term=NCT00441116&rank=1 NLM Identifier: NCT00441116. 2012. Bethesda. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
30 GSK Clinical Trials. Long-Term Study of Gabapentin Enacarbil (GEn, XP13512) vs. Placebo in Patients With Restless Legs Syndrome. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00311363?term=NCT00311363&rank=1 NLM Identifier: NCT00311363. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
31 Horn P. Efficacy Study of DX-88 (Ecallantide) to Treat Acute Attacks of Hereditary Angioedema (HAE). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00457015?term=NCT00457015&rank=1 NLM Identifier: NCT00457015. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
32 Janssen-Cilag International NV. A Study to Evaluate Effectiveness and Safety of Prolonged Release OROS Methylphenidate in Adults With Attention Deficit Hyperactivity Disorder. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00714688?term=NCT00714688&rank=1 NLM Identifier: NCT00714688. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
33 Labopharm Inc. A Randomized, Double-blind, Two-arm Study Comparing the Efficacy and Safety of Trazodone Contramid® OAD and Placebo in the Treatment of Unipolar Major Depressive Disorder. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00775203?term=NCT00775203&rank=1 NLM Identifier: NCT00775203. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
34 Luyten F. RCT of ChondroCelect® (in an ACI Procedure) vs Microfracture in the Repair of Cartilage Defects of the Knee (TIGACT01). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00414700?term=NCT00414700&rank=1 NLM Identifier: NCT00414700. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
35 Lyby K. Safety of Insulin Detemir Produced by a New Process as Measured by Antibody Formation in Subjects With Type 1 Diabetes. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00447382?term=NCT00447382&rank=1 NLM Identifier: NCT00447382. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
36 Medical Monitor Merk. A Study of the Effects of Oral Prednisone in Patients With Rheumatoid Arthritis (MK0000-088)(COMPLETED). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00746512?term=NCT00746512&rank=1 NLM Indentifier: NCT00746512. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
37 Novartis. Enteric-coated Mycophenolate Sodium (EC-MPS) and Mycophenolate Mofetil (MMF) in Renal Transplant Patients With Gastrointestinal (GI) Intolerance. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00400400?term=NCT00400400&rank=1 NLM Identifier: NCT00400400. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
38 Novartis. Study of Combination Therapy With LdT Plus Adefovir Versus Adefovir Alone. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00376259?term=NCT00376259&rank=1 NLM Identifier: NCT00376259. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 20. 2012. Ref Type: Online Source.
39 Novartis. Aliskiren/Amlodipine/Hydrochlorothiazide (HCTZ) Versus Aliskiren/Amlodipine in US Minority Patients With Stage II Systolic Hypertension (ASCENT). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00942994?term=NCT00942994&rank=1 NLM Identifier: NCT00942994. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
40 Novartis. Study of the Efficacy and Safety of Aliskiren HCTZ vs Ramipril in Obese Patients (BMI ? 30) With Stage 2 Hypertension (ATTAIN). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00772577?term=NCT00772577&rank=1 NLM Identifier: NCT00772577. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
41 Novartis. 8 Weeks Study to Evaluate the Efficacy and Safety of Valsartan in Combination With Aliskiren Compared to Valsartan Alone in Patients With Stage 2 Hypertension (VANTAGE). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00809926?term=NCT00809926&rank=1 NLM Identifier: NCT00809926. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
42 Novartis. Blood Pressure Lowering of Aliskiren Hydrochlorothiazide (HCTZ) Versus Amlodipine in Stage 2 Hypertension in African Americans (ATLAAST). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00739596?term=NCT00739596&rank=1 NLM Indentifier: NCT00739596. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
43 Novartis. Enteric-coated Mycophenolate Sodium (EC-MPS) With Reduced-dose Tacrolimus Versus EC-MPS With Standard-dose Tacrolimus in Stable Kidney Transplant Recipients (OLYMPE). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00284934?term=NCT00284934.&rank=1 NLM Identifier: NTC00284934. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
44 Novartis. Efficacy/Safety of Verteporfin Photodynamic Therapy and Ranibizumab Compared With Ranibizumab in Patients With Subfoveal Choroidal Neovascularization. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00436553?term=NCT00436553&rank=1 NLM Identifier: NCT00436553. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
45 Novartis. Verteporfin Photodynamic Therapy Administered in Conjunction With Ranibizumab in Patients With Subfoveal Choroidal Neovascularization Secondary to Age-related Macular Degeneration (AMD). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00433017?term=NCT00433017&rank=1 NLM Identifier: NCT00433017. 2012. Bathesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
46 Novartis Customer Infomation. Safety and Efficacy of Ranibizumab in Japanese Patients With Subfoveal Choroidal Neovascularization Secondary to Age-related Macular Degeneration. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00284089?term=NCT00284089&rank=1 NLM Identifier: NCT00284089. 2012. Bethesda. National Library of Medicine (U.S.). 2252. Ref Type: Online Source.
47 Novartis Pharma. Omalizumab Use and Asthma-Related Quality of Life in Patients With Severe Persistent Allergic Asthma. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00567476?term=NCT00567476&rank=1 NLM: Identifier: NCT00567476. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
48 Novartis Pharma. Efficacy and Safety of Ranibizumab (Intravitreal Injections) in Patients With Visual Impairment Due to Diabetic Macular Edema (RESTORE). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00687804?term=NCT00687804&rank=1 NLM Identifier: NTC00687804. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
49 Novartis Pharma. Efficacy and Safety of Valsartan/Hydrochlorothiazide Combination Compared to Valsartan Monotherapy or Hydrochlorothiazide Monotherapy in Elderly (>70) With Mild-moderate Hypertension. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00698646?term=NCT00698646&rank=1 NLM Identifier: NCT00698646. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
50 Novartis Pharma. The Efficacy of Oral Everolimus in Patients With Neovascular Age-related Macular Degeneration. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00857259?term=NCT00857259&rank=1 NLM Identifier: NCT00857259. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
51 Novartis Pharma. Nordic Everolimus (Certican) Trial in Heart and Lung Transplantation (NOCTET). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00377962?term=NCT00377962&rank=1 NLM Identifier: NCT00377962. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
52 Novartis Pharma. A Safety and Efficacy Study Comparing the Combination Treatments of Verteporfin Therapy Plus One of Two Different Doses of Intravitreal Triamcinolone Acetonide and the Verteporfin Therapy Plus Intravitreal Pegaptanib (VERITAS). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00242580?term=NCT00242580&rank=1 NLM Identifier: NCT00242580. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
53 Novartis Pharma. Omalizumab in Adult and Adolescent Patients With Severe Persistent Allergic Asthma. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00264849?term=NCT00264849&rank=1 NLM Identifier: NCT00264849. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
54 Novartis Pharma. Safety/Efficacy of Valsartan/Hydrochlorothiazide Combination Compared to Hydrochlorothiazide in Obese Hypertensive Adults. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00439738?term=NCT00439738&rank=1 NLM Identifier: NCT00439738. 2012. Bethesda. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
55 Novartis Pharma. Viral Kinetics Study of Telbivudine and Entecavir in Adults With Chronic Hepatitis B. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00412529?term=NCT00412529&rank=1 NLM Identifier: NCT00412529. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
56 Novartis Pharma. Effects of Zoledronic Acid and Raloxifene on Bone Turnover Markers in Postmenopausal Women With Low Bone Mineral Density. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00431444?term=NCT00431444&rank=1 NLM Identifier: NTC00431444. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
57 Novartis Pharma. Efficacy and Safety of Rivastigmine Transdermal Patch in Patients With Mild to Moderate Alzheimer's Disease. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00423085?term=NCT00423085&rank=1 NLM Identifier: NCT00423085. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
58 Novartis Pharma. Valsartan/Amlodipine As Compared to Losartan Treatment in Stage 2 Systolic Hypertension (EXALT). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00931710?term=NCT00931710&rank=1 NLM Identifier: NCT00931710. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
59 Oparil S. The Effects of Moderate vs. Aggressive Treatment With Valsartan + Amlodipine on Patients With Hypertension Uncontrolled by Angiotensin-Receptor Blocker (Herein, ARB) Monotherapy (EXTRA). ClinicalTrials.gove. http://clinicaltrials.gov/ct2/show/NCT00666536?term=NCT00666536&rank=1 NLM Identifier: NCT00666536. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
60 Ortho-McNeil Janssen Scientific Affairs. Adult Study / OROS Methylphenidate Hydrochloride (HCL) (OROS MPH) in Adults With Attention Deficit Hyperactivity Disorder (ADHD). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00937040?term=NCT00937040&rank=1 NLM Identifier: NCT00937040. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
61 Pfizer. Exubera Large Simple Trial To Evaluate Long-Term Pulmonary And Cardiovascular Safety (VOLUME). ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00359801?term=NCT00359801&rank=1 NLM Identifier: NCT00359801. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
62 Pfizer. A One Year Clinical Trial Assessing the Usefulness and Safety of Inhaled Insulin in Diabetics With Asthma. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00139659?term=NCT00139659&rank=1 NLM: Identifier: NCT00139659. 2012. Bethesda MD. National Library of Medicine (U.S.). Ref Type: Online Source.
63 Reiss W. A Study of the Safety and Efficacy of Rituximab in Patients With Moderate to Severe Rheumatoid Arthritis Receiving Methotrexate. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00243412?term=NCT00243412&rank=1 NLM Identifier: NCT00243412. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
64 Robin J. Randomized, Placebo-Controlled Study of AbobotulinumtoxinA (Dysport®) for the Treatment of Cervical Dystonia. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00257660?term=NCT00257660&rank=1 NLM Identifier: NCT00257660. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
65 Squibb B. Atazanavir (BMS-232632) in Combination With Ritonavir or Saquinavir, and Lopinavir/Ritonavir, Each With Tenofovir and a Nucleoside in Subjects With HIV. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00035932?term=NCT00035932&rank=1 NLM Identifer: NCT00035932. 2012. Bethesda. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
66 UCB Clinical Trial. Efficacy, Safety and Tolerability of Rotigotine Nasal Spray for the Acute Treatment of Parkinson Symptoms. ClinicalTrials.gov. http://clinicaltrials.gov/ct2/show/NCT00296192?term=NCT00296192&rank=1 NLM Identifier: NCT00296192. 2012. Bethesda MD. National Library of Medicine (U.S.). 2. 25. 2012. Ref Type: Online Source.
67 Abboud H, Coyne D, Smolenski O, et al. A comparison of dosing regimens of paricalcitol capsule for the treatment of secondary hyperparathyroidism in CKD stages 3 and 4. American Journal of Nephrology. 2006;26:105-114. [pmid: 16543714].
68 Angoulvant D, Cucherat M, Rioufol G, et al. Preventing acute decrease in renal function induced by coronary angiography (PRECORD): a prospective randomized trial. Archives of cardiovascular diseases. 2009;102:761-767. [pmid: 19944392].
69 Apfel SC, Schwartz S, Adornato BT, et al. Efficacy and safety of recombinant human nerve growth factor in patients with diabetic polyneuropathy: A randomized controlled trial. rhNGF Clinical Investigator Group. JAMA. 2000;284:2215-2221. [pmid: 11056593].
70 Appel LJ, Champagne CM, Harsha DW, et al. Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. 2003;289:2083-2093. [pmid: 12709466].
71 Barbe F, Mayoralas LR, Duran J, et al. Treatment with continuous positive airway pressure is not effective in patients with sleep apnea but no daytime sleepiness. a randomized, controlled trial. Annals of Internal Medicine. 2001;134:1015-1023. [pmid: 11388814].
72 Barrett BJ, Katzberg RW, Thomsen HS, et al. Contrast-induced nephropathy in patients with chronic kidney disease undergoing computed tomography: a double-blind comparison of iodixanol and iopamidol. [Erratum appears in Invest Radiol. 2007 Feb;42(2):94 Note: Ni, Zhao-hui [added]]. Investigative Radiology. 2006;41:815-821. [pmid: 17035872].
73 Bellinghieri G, Mazzaglia G, Savica V, Santoro D. Effects of manidipine and nifedipine on blood pressure and renal function in patients with chronic renal failure: a multicenter randomized controlled trial. Renal Failure. 2003;25:681-689. [pmid: 14575277].
74 Bertrand OF, Rodes-Cabau J, Larose E, et al. Intracoronary compared to intravenous Abciximab and high-dose bolus compared to standard dose in patients with ST-segment elevation myocardial infarction undergoing transradial primary percutaneous coronary intervention: a two-by-two factorial placebo-controlled randomized study. American Journal of Cardiology. 2010;105:1520-1527. [pmid: 20494655].
75 Boccalandro F, Amhad M, Smalling RW, Sdringola S. Oral acetylcysteine does not protect renal function from moderate to high doses of intravenous radiographic contrast. Catheterization & Cardiovascular Interventions. 2003;58:336-341. [pmid: 12594698].
76 Bour B, Staub JL, Chousterman M, et al. Long-term treatment of gastro-oesophageal reflux disease patients with frequent symptomatic relapses using rabeprazole: on-demand treatment compared with continuous treatment. Alimentary Pharmacology & Therapeutics. 2005;21:805-812. [pmid: 15801915].
77 Brandt JR, Avner ED, Hickman RO, Watkins SL. Safety and efficacy of erythropoietin in children with chronic renal failure. Pediatric Nephrology. 1999;13:143-147. [pmid: 10229004].
78 Brar SS, Shen AY, Jorgensen MB, et al. Sodium bicarbonate vs sodium chloride for the prevention of contrast medium-induced nephropathy in patients undergoing coronary angiography: a randomized trial. JAMA. 2008;300:1038-1046. [pmid: 18768415].
79 Brass EP, Adler S, Sietsema KE, et al. Intravenous L-carnitine increases plasma carnitine, reduces fatigue, and may preserve exercise capacity in hemodialysis patients. American Journal of Kidney Diseases. 2001;37:1018-1028. [pmid: 11325685].
80 Christensen JH, Christensen MS, Dyerberg J, Schmidt EB. Heart rate variability and fatty acid content of blood cell membranes: a dose-response study with n-3 fatty acids. American Journal of Clinical Nutrition. 1999;70:331-337. [pmid: 10479194].
81 Coyne D, Acharya M, Qiu P, et al. Paricalcitol capsule for the treatment of secondary hyperparathyroidism in stages 3 and 4 CKD. American Journal of Kidney Diseases. 2006;47:263-276. [pmid: 16431255].
82 Coyne DW, Kapoian T, Suki W, et al. Ferric gluconate is highly efficacious in anemic hemodialysis patients with high serum ferritin and low transferrin saturation: results of the Dialysis Patients' Response to IV Iron with Elevated Ferritin (DRIVE) Study. Journal of the American Society of Nephrology. 2007;18:975-984. [pmid: 17267740].
83 Culleton BF, Walsh M, Klarenbach SW, et al. Effect of frequent nocturnal hemodialysis vs conventional hemodialysis on left ventricular mass and quality of life: a randomized controlled trial. JAMA. 2007;298:1291-1299. [pmid: 17878421].
84 de Godoy DV, de Godoy RF. A randomized controlled trial of the effect of psychotherapy on anxiety and depression in chronic obstructive pulmonary disease. Archives of Physical Medicine & Rehabilitation. 2003;84:1154-1157. [pmid: 12917854].
85 Dejesus RS, Chaudhry R, Leutink DJ, Hinton MA, Cha SS, Stroebel RJ. Effects of efforts to intensify management on blood pressure control among patients with type 2 diabetes mellitus and hypertension: a pilot study. Vascular Health & Risk Management. 2009;5:705-711. [pmid: 19756162].
86 Dussol B, Morange S, Loundoun A, Auquier P, Berland Y. A randomized trial of saline hydration to prevent contrast nephropathy in chronic renal failure patients. Nephrology Dialysis Transplantation. 2006;21:2120-2126.
87 Feiten SF, Draibe SA, Watanabe R, et al. Short-term effects of a very-low-protein diet supplemented with ketoacids in nondialyzed chronic kidney disease patients. European Journal of Clinical Nutrition. 2005;59:129-136. [pmid: 15354199].
88 Ferraris JR, Pasqualini T, Legal S, et al. Effect of deflazacort versus methylprednisone on growth, body composition, lipid profile, and bone mass after renal transplantation. The Deflazacort Study Group. Pediatric Nephrology. 2000;14:682-688. [pmid: 10912543].
89 FHN Trial Group, Chertow GM, Levin NW, et al. In-center hemodialysis six times per week versus three times per week. [Erratum appears in N Engl J Med. 2011 Jan 6;364(1):93]. New England Journal of Medicine. 2010;363:2287-2300. [pmid: 21091062].
90 Geelen A, Brouwer IA, Schouten EG, Maan AC, Katan MB, Zock PL. Effects of n-3 fatty acids from fish on premature ventricular complexes and heart rate in humans. American Journal of Clinical Nutrition. 2005;81:416-420. [pmid: 15699229].
91 Goyens PL, Mensink RP. Effects of alpha-linolenic acid versus those of EPA/DHA on cardiovascular risk markers in healthy elderly subjects. European Journal of Clinical Nutrition. 2006;60:978-984. [pmid: 16482073].
92 Hansson L, Zanchetti A, Carruthers SG, et al. Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet. 1998;351:1755-1762. [pmid: 9635947].
93 Hawkey C, Talley NJ, Yeomans ND, et al. Improvements with esomeprazole in patients with upper gastrointestinal symptoms taking non-steroidal antiinflammatory drugs, including selective COX-2 inhibitors. American Journal of Gastroenterology. 2005;100:1028-1036. [pmid: 15842575].
94 Hsiao SF, Wu YT, Wu HD, Wang TG. Comparison of effectiveness of pressure threshold and targeted resistance devices for inspiratory muscle training in patients with chronic obstructive pulmonary disease. Journal of the Formosan Medical Association. 2003;102:240-245. [pmid: 12833187].
95 Johnson DA, Orr WC, Crawley JA, et al. Effect of esomeprazole on nighttime heartburn and sleep quality in patients with GERD: a randomized, placebo-controlled trial. American Journal of Gastroenterology. 2005;100:1914-1922. [pmid: 16128933].
96 Kurihara S, Tsuruta Y, Akizawa T. Effect of MCI-196 (colestilan) as a phosphate binder on hyperphosphataemia in aemodialysis patients: a double-blind, placebo-controlled, short-term trial. Nephrology Dialysis Transplantation. 2005;20:424-430.
97 Mak SK, Wong PN, Lo KY, Tong GM, Fung LH, Wong AK. Randomized prospective study of the effect of increased dialytic dose on nutritional and clinical outcome in continuous ambulatory peritoneal dialysis patients. American Journal of Kidney Diseases. 2000;36:105-114. [pmid: 10873879].
98 Mann JF, Green D, Jamerson K, et al. Avosentan for overt diabetic nephropathy. Journal of the American Society of Nephrology. 2010;21:527-535. [pmid: 20167702].
99 Marre M, Puig JG, Kokot F, et al. Equivalence of indapamide SR and enalapril on microalbuminuria reduction in hypertensive patients with type 2 diabetes: the NESTOR Study. Journal of Hypertension. 2004;22:1613-1622. [pmid: 15257186].
100 Masuda M, Yamada T, Mine T, et al. Comparison of usefulness of sodium bicarbonate versus sodium chloride to prevent contrast-induced nephropathy in patients undergoing an emergent coronary procedure. American Journal of Cardiology. 2007;100:781-786. [pmid: 17719320].
101 McManus RJ, Mant J, Bray EP, et al. Telemonitoring and self-management in the control of hypertension (TASMINH2): a randomised controlled trial. Lancet. 2010;376:163-172. [pmid: 20619448].
102 Mircescu G, Garneata L, Ciocalteu A, et al. Once-every-2-weeks and once-weekly epoetin beta regimens: equivalency in hemodialyzed patients. American Journal of Kidney Diseases. 2006;48:445-455. [pmid: 16931218].
103 Mulder HJ, Schalij MJ, van der LA, Hollaar L, Zwinderman AH, Bruschke AV. Improvement of serum oxidation by pravastatin might be one of the mechanisms by which endothelial function in dilated coronary artery segments is ameliorated. Atherosclerosis. 2003;169:309-315. [pmid: 12921983].
104 Ninio DM, Hill AM, Howe PR, Buckley JD, Saint DA. Docosahexaenoic acid-rich fish oil improves heart rate variability and heart rate responses to exercise in overweight adults. British Journal of Nutrition. 2008;100:1097-1103. [pmid: 18339222].
105 Nissen SE. Effect of intensive lipid lowering on progression of coronary atherosclerosis: evidence for an early benefit from the Reversal of Atherosclerosis with Aggressive Lipid Lowering (REVERSAL) trial. [Review] [20 refs]. American Journal of Cardiology. 2005;96:61F-68F. [pmid: 15979434].
106 Noakes M, Keogh JB, Foster PR, Clifton PM. Effect of an energy-restricted, high-protein, low-fat diet relative to a conventional high-carbohydrate, low-fat diet on weight loss, body composition, nutritional status, and markers of cardiovascular health in obese women. American Journal of Clinical Nutrition. 2005;81:1298-1306. [pmid: 15941879].
107 Oh EG. The effects of home-based pulmonary rehabilitation in patients with chronic lung disease. International Journal of Nursing Studies. 2003;40:873-879. [pmid: 14568368].
108 Pedersen H, Petersen M, Major-Pedersen A, et al. Influence of fish oil supplementation on in vivo and in vitro oxidation resistance of low-density lipoprotein in type 2 diabetes. European Journal of Clinical Nutrition. 2003;57:713-720. [pmid: 12771973].
109 Pijls LT, de VH, Donker AJ, van Eijk JT. The effect of protein restriction on albuminuria in patients with type 2 diabetes mellitus: a randomized trial. Nephrology Dialysis Transplantation. 1999;14:1445-1453.
110 Provenzano R, Bhaduri S, Singh AK, PROMPT Study Group. Extended epoetin alfa dosing as maintenance treatment for the anemia of chronic kidney disease: the PROMPT study. Clinical Nephrology. 2005;64:113-123. [pmid: 16114787].
111 Provenzano R, Schiller B, Rao M, Coyne D, Brenner L, Pereira BJ. Ferumoxytol as an intravenous iron replacement therapy in hemodialysis patients. Clinical Journal of The American Society of Nephrology: CJASN. 2009;4:386-393. [pmid: 19176796].
112 Qunibi W, Moustafa M, Muenz LR, et al. A 1-year randomized trial of calcium acetate versus sevelamer on progression of coronary artery calcification in hemodialysis patients with comparable lipid control: the Calcium Acetate Renagel Evaluation-2 (CARE-2) study. American Journal of Kidney Diseases. 2008;51:952-965. [pmid: 18423809].
113 Scholten T, Gatz G, Hole U. Once-daily pantoprazole 40 mg and esomeprazole 40 mg have equivalent overall efficacy in relieving GERD-related symptoms. Alimentary Pharmacology & Therapeutics. 2003;18:587-594. [pmid: 12969085].
114 Shah MR, O'Connor CM, Sopko G, Hasselblad V, Califf RM, Stevenson LW. Evaluation Study of Congestive Heart Failure and Pulmonary Artery Catheterization Effectiveness (ESCAPE): design and rationale. American Heart Journal. 2001;141:528-535. [pmid: 11275915].
115 Spargias K, Adreanides E, Demerouti E, et al. Iloprost prevents contrast-induced nephropathy in patients with renal dysfunction undergoing coronary angiography or intervention. Circulation. 2009;120:1793-1799. [pmid: 19841299].
116 Spinowitz B, Germain M, Benz R, et al. A randomized study of extended dosing regimens for initiation of epoetin alfa treatment for anemia of chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. 2008;3:1015-1021. [pmid: 18400964].
117 Spinowitz BS, Kausz AT, Baptista J, et al. Ferumoxytol for treating iron deficiency anemia in CKD. Journal of the American Society of Nephrology. 2008;19:1599-1605. [pmid: 18525001].
118 Stevens MA, McCullough PA, Tobin KJ, et al. A prospective randomized trial of prevention measures in patients at high risk for contrast nephropathy: results of the P.R.I.N.C.E. Study. Prevention of Radiocontrast Induced Nephropathy Clinical Evaluation. Journal of the American College of Cardiology. 1999;33:403-411. [pmid: 9973020].
119 Tanaka Y, Yoshikawa N, Hattori S, et al. Combination therapy with steroids and mizoribine in juvenile SLE: a randomized controlled trial. [Erratum appears in Pediatr Nephrol. 2010 May;25(5):995]. Pediatric Nephrology. 2010;25:877-882. [pmid: 19902267].
120 Tatti P, Pahor M, Byington RP, et al. Outcome results of the Fosinopril Versus Amlodipine Cardiovascular Events Randomized Trial (FACET) in patients with hypertension and NIDDM. Diabetes Care. 1998;21:597-603. [pmid: 9571349].
121 Thjodleifsson B, Beker JA, Dekkers C, Bjaaland T, Finnegan V, Humphries TJ. Rabeprazole versus omeprazole in preventing relapse of erosive or ulcerative gastroesophageal reflux disease: a double-blind, multicenter, European trial. The European Rabeprazole Study Group. Digestive Diseases & Sciences. 2000;45:845-853. [pmid: 10795744].
122 Ueda H, Yamada T, Masuda M, et al. Prevention of contrast-induced nephropathy by bolus injection of sodium bicarbonate in patients with chronic kidney disease undergoing emergent coronary procedures. American Journal of Cardiology. 2011;107:1163-1167. [pmid: 21349483].
123 van Aalderen WM, Price D, De Baets FM, Price J. Beclometasone dipropionate extrafine aerosol versus fluticasone propionate in children with asthma. Respiratory Medicine. 2007;101:1585-1593. [pmid: 17254760].
124 Wang A, Holcslaw T, Bashore TM, et al. Exacerbation of radiocontrast nephrotoxicity by endothelin receptor antagonism. Kidney International. 2000;57:1675-1680. [pmid: 10760103].
125 Warady BA, Kausz A, Lerner G, et al. Iron therapy in the pediatric hemodialysis population. Pediatric Nephrology. 2004;19:655-661. [pmid: 15064942].
126 Wilder-Smith CH, Wilder-Smith P, Kawakami-Wong H, Voronets J, Osann K, Lussi A. Quantification of dental erosions in patients with GERD using optical coherence tomography before and after double-blind, randomized treatment with esomeprazole or placebo. American Journal of Gastroenterology. 2009;104:2788-2795. [pmid: 19654570].
127 Zanotti E, Felicetti G, Maini M, Fracchia C. Peripheral muscle strength training in bed-bound patients with COPD receiving mechanical ventilation: effect of electrical stimulation. Chest. 2003;124:292-296. [pmid: 12853536].