# Additional Simulation Results

This Appendix presents additional simulation results for smaller (5 studies) and larger (20 studies) meta-analyses for the scenarios presented in the main report. We also present complete numerical results for all scenarios and all meta-analysis sizes, both under fixed and random effects meta-analyses.

For all figures in this file we use the following abbreviations and conventions: SS, sample size, SSR, sample size ratio; VR, variance ratio; ρ, correlation parameter value; τ^2^, between-study variance of the treatment effect. ○ = meta-analyses where within-group correlations were reported from all studies; △ = meta-analyses where 50% of the within-group correlations were missing; □ = meta-analyses where all within-group correlations were missing.

## Simulation Results for Smaller (5 Studies)

Bias

Figure B-1 Average bias across 1000 simulated meta-analyses under various scenarios (ρ=0, meta-analyses with 5 studies)

Nine subplots are displayed with treatment effect (ranging from 0 to 1) on the x axis and bias (ranging from -0.1 to 0.1) on the y axis. Each subplot displays the different scenarios where τ2 = 0, 0.1, or 0.5, and where sample size = 20, 50, or 100. Within each plot the simulated meta-analyses under three scenarios (within-group correlations were reported from all studies, 50% of the within-group correlations were missing, and all within-group correlations were missing) at four different treatment effects (0, 0.1, 0.5, and 1). In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. Also, all scenarios show no or very small bias (less than about 0.01).

Figure B-2 Average bias across 1000 simulated meta-analyses under various scenarios (ρ=0.40, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 1. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. Also, all but one scenario show no or very small bias (less than about 0.01). In the scenario of τ2 = 0.5 and sample size = 100, the bias when the treatment effect = 1 is approximately 0.025.

Figure B-3 Average bias across 1000 simulated meta-analyses under various scenarios (ρ=0.59, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 1. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. Also, all but one scenario show no or very small bias (less than about 0.01). In the scenario of τ2 = 0.5 and sample size = 100, the bias when the treatment effect = 1 is approximately 0.025.

Figure B-4 Average bias across 1000 simulated meta-analyses under various scenarios (ρ=0.81, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 1. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. Also, all scenarios show no or very small bias (less than about 0.01).

Coverage probability

Figure B-5 Coverage probabilities across 1000 simulated meta-analyses under various scenarios (ρ=0, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 1, except that the y axis displays coverage probability ranging from 0.85 to 1, where nominal coverage is 0.95. In all scenarios the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed). When τ2 = 0 and all correlations are reported (none is imputed) coverage is approximately 0.95 to 0.97. In all other scenarios, coverage is <0.95. When τ2 = 0, coverage generally ranges from about 0.91 to 0.97. When τ2 = 0.1, coverage generally ranges from about 0.87 to 0.94. When τ2 = 0.5, coverage generally ranges from about 0.87 to 0.91. In general, coverage is somewhat lower with larger sample sizes.

Figure B-6 Coverage probabilities across 1000 simulated meta-analyses under various scenarios (ρ=0.40, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 5. In all scenarios the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed); although the spread of coverage values is narrower than when ?=0. When τ2 = 0 coverage is about 0.94 to 0.97. When τ2 = 0.1, coverage generally ranges from about 0.88 to 0.92. When τ2 = 0.5, coverage generally ranges from about 0.86 to 0.89. In general, coverage is somewhat lower with larger sample sizes.

Figure B-7 Coverage probabilities across 1000 simulated meta-analyses under various scenarios (ρ=0.59, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 5. In all scenarios the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed); although the spread of coverage values is narrower than when ?=0. When τ2 = 0 coverage is about 0.95 to 0.98. When τ2 = 0.1, coverage generally ranges from about 0.87 to 0.93. When τ2 = 0.5, coverage generally ranges from about 0.85 to 0.91. In general, coverage is somewhat lower with larger sample sizes.

Figure B-8 Coverage probabilities across 1000 simulated meta-analyses under various scenarios (ρ=0.81, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 5. In all scenarios the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed), with a relatively wide spread of about 5 percentage points along the y axis when τ2 = 0 or τ2 = 0.1; when τ2 = 0.5, there is little spread across these scenarios. When τ2 = 0 coverage is about 0.96 to 1.0. When τ2 = 0.1, coverage generally ranges from about 0.87 to 0.95. When τ2 = 0.5, coverage generally ranges from about 0.86 to 0.90. In general, coverage is somewhat lower with larger sample sizes.

Mean square error (MSE)

Figure B-9 Mean squared error across 1000 simulated meta-analyses under various scenarios (ρ=0, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 1, except that the y axis displays mean squared error ranging from 0 to 0.2. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. In all scenarios where τ2 = 0, the mean squared error was between 0 and about 0.02. In all scenarios where τ2 = 0.1, the mean squared error was about 0.03 to 0.06. In all scenarios where τ2 = 0.5, the mean squared error was between about 0.1 and 0.15. In general, mean squared error was somewhat lower with larger sample sizes.

Figure B-10 Mean squared error across 1000 simulated meta-analyses under various scenarios (ρ=0.40, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 9. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. In all scenarios where τ2 = 0 or τ2 = 0.1, the mean squared error was about 0.02. In all scenarios where τ2 = 0.5, the mean squared error was between about 0.1.

Figure B-11 Mean squared error across 1000 simulated meta-analyses under various scenarios (ρ=0.59, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 9. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. In all scenarios where τ2 = 0 or τ2 = 0.1, the mean squared error was about 0.02. In all scenarios where τ2 = 0.5, the mean squared error was between about 0.1.

Figure B-12 Mean squared error across 1000 simulated meta-analyses under various scenarios (ρ=0.81, meta-analyses with 5 studies)

The same nine subplots are displayed as in Appendix Figure 9. In all scenarios the simulated meta-analyses with different percentages of missing correlations were nearly identical. In all scenarios where τ2 = 0, the mean squared error was about 0.01. In all scenarios where τ2 = 0.1, the mean squared error was about 0.02.In all scenarios where τ2 = 0.5, the mean squared error was between about 0.1.

## Simulation Results for Larger (20 Studies)

Bias

Figure B-13 Average bias across 1000 simulated meta-analyses under various scenarios (ρ=0, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 1. In all scenarios, the bias is approximately 0.

Figure B-14 Average bias across 1000 simulated meta-analyses under various scenarios (ρ=0.40, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 13. The results of all scenarios are nearly identical to Appendix Figure 13, the bias is approximately 0.

Figure B-15 Average bias across 1000 simulated meta-analyses under various scenarios (ρ=0.59, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 13. The results of all scenarios are nearly identical to Appendix Figure 13, the bias is approximately 0.

Figure B-16 Average bias across 1000 simulated meta-analyses under various scenarios (ρ=0.81, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 13. The results of all scenarios are nearly identical to Appendix Figure 13, the bias is approximately 0.

Coverage probability

Figure B-17 Coverage probabilities across 1000 simulated meta-analyses under various scenarios (ρ=0, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 5. In scenarios where τ2 = 0, the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed). The spread across these scenarios is approximately 3 percentage points along the y axis. Overall, when τ2 = 0 coverage generally ranges from about 0.94 to 0.97. When τ2 = 0.1 or τ2 = 0.5, coverage generally ranges from about 0.92 to 0.95. In general, coverage is similar with different sample sizes.

Figure B-18 Coverage probabilities across 1000 simulated meta-analyses under various scenarios (ρ=0.40, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 17. In all scenarios the coverage probabilities when all within-group correlations were missing, when 50% of correlations are missing, and when all correlations were reported (no imputation of correlation was needed) are similar to each other. When τ2 = 0 coverage is about 0.93 to 0.97. When τ2 = 0.1 or τ2 = 0.5, coverage generally ranges from about 0.93 to 0.95. In general, coverage is similar with different sample sizes.

Figure B-19 Coverage probabilities across 1000 simulated meta-analyses under various scenarios (ρ=0.59, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 17. In scenarios where τ2 = 0, the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed). The spread across these scenarios is approximately 3 percentage points along the y axis. With larger τ2 the scenarios are very similar. When τ2 = 0 coverage is about 0.95 to 0.97. When τ2 = 0.1 or τ2 = 0.5, coverage generally ranges from about 0.93 to 0.95. In general, coverage is similar with different sample sizes.

Figure B-20 Coverage probabilities across 1000 simulated meta-analyses under various scenarios (ρ=0.81, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 17. In scenarios where τ2 = 0, the coverage probabilities when all within-group correlations were missing are lower than when 50% of correlations are missing, which in turn are lower than when all correlations were reported (no imputation of correlation was needed). The spread across these scenarios is approximately 5 percentage points along the y axis. With larger τ2 the scenarios are very similar, except when τ2 = 0.1 and sample size = 20, where the spread is about 2 percentage pionts. When τ2 = 0 coverage is about 0.95 to 1.0. When τ2 = 0.1 or τ2 = 0.5, coverage generally ranges from about 0.92 to 0.94. In general, coverage is similar with different sample sizes.

Mean square error (MSE)

Figure B-21 Mean squared error across 1000 simulated meta-analyses under various scenarios (ρ=0, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 9. In scenarios where τ2 = 0 or τ2 = 0.1, the mean squared error was less than about 0.02. When τ2 = 0.5, the mean squared error was about 0.4.

Figure B-22 Mean squared error across 1000 simulated meta-analyses under various scenarios (ρ=0.40, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 21. In scenarios where τ2 = 0 or τ2 = 0.1, the mean squared error was less than about 0.02. When τ2 = 0.5, the mean squared error was about 0.4.

Figure B-23 Mean squared error across 1000 simulated meta-analyses under various scenarios (ρ=0.59, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 21. In scenarios where τ2 = 0 or τ2 = 0.1, the mean squared error was less than about 0.02. When τ2 = 0.5, the mean squared error was about 0.4.

Figure B-24 Mean squared error across 1000 simulated meta-analyses under various scenarios (ρ=0.81, meta-analyses with 20 studies)

The same nine subplots are displayed as in Appendix Figure 21. In scenarios where τ2 = 0 or τ2 = 0.1, the mean squared error was less than about 0.02. When τ2 = 0.5, the mean squared error was about 0.4.

## Complete Simulation Results

The tables in the following pages present the complete simulation results for each scenario assessed, three different meta-analysis sizes (5, 10, 20 studies), and using fixed and random effects methods.

In all tables MSE denotes mean square error; Tx is the treatment effect; ρ is the correlation parameter; SS is the sample size; SSR is the sample size ratio; and τ^2^ is the between-study heterogeneity parameter.

Simulation results: 5 studies per meta-analysis, fixed effect

Simulation results: 5 studies per meta-analysis, random effects

Simulation results: 10 studies per meta-analysis, fixed effect

Simulation results: 10 studies per meta-analysis, random effects

Simulation results: 20 studies per meta-analysis, fixed effect

Simulation results: 20 studies per meta-analysis, random effects