# Detailed Simulation Methods

We simulated meta-analyses of J parallel-group design randomized trials with two treatment groups (treatment, T, and control, C, with corresponding sample sizes N_T_ and N_C_, same for all studies in a meta-analysis) and a continuous outcome, measured at baseline (T1 and C1, respectively) and after follow-up (T2 and C2, respectively). We assume the same data generating mechanism (model) for all studies, which is described below.

We assume that the study groups are independent (i.e. patients are either treated or non-treated), all patients are compliant to the treatment assignment, and have complete followup (no drop-outs). Cases of imperfect compliance would tend to make the outcomes in the compared groups similar, but they would not affect the overall conclusions of the simulation study. Further, we assume that the outcome values for the i-th control individual in the j-th study, at baseline (m_C1,ij_) and after followup (m_C2,ij_) are generated by a bivariate normal distribution:

( m_C 1 , i j_ m_C 2 , i j_ ) ~ B V N ( ( μ_C 1 , j_ μ_C 2 , j_ ) , ∑_C_j__ )

Here, μ_c1,j_ and μ_c2,j_ are the “true” pre- and post-treatment means in the control arm, and ∑_c_j__ is their covariance matrix:

∑_C_j__ = ( σ_C 1 , j_^2^ ρ_C_ σ_C 1 , j_ σ_C 2 , j_ ρ_C_ σ_C 1 , j_ σ_C 2 , j_ σ_C 2 , j_^2^ )

σ_C 1 , j_^2^ and σ_C 2 , j_^2^ are the variances of the pre- and post-treatment measurements, and ρ_C_ is the correlation between pre- and post- treatment measurements. For simplicity, and since the control arm does not undergo intervention we assume that the variance in the j-th study remains constant over time ( σ_C 1 , j_^2^ = σ_C 2 , j_^2^ = σ_C j_^2^ );thus, the covariance matrix can be written as

∑_C_j__ = ( σ_C j_^2^ ρ_C_ σ_C j_^2^ ρ_C_ σ_C j_^2^ σ_C j_^2^ )

Similar to the control arm, the general data generating form for the i-th individual on the treatment arm of the j-th study is

( m_T 1 , i j_ m_T 2 , i j_ ) ~ B V N ( ( μ_T 1 , j_ μ_T 2 , j_ ) , ∑_T j_ )

However, because we are interested in modeling randomized trials, the “true” pre-treatment means in the treatment and control groups can be assumed to be equal: μ_C1,j_ = μ_T1,j_. Further the pre-treatment variances can also be considered to be equal: σ_C 1 , j_^2^ = σ_T 1 , j_^2^ . However, we allow for the treatment to (potentially) have an impact on the post-treatment mean and variance of individuals in the treatment group. Thus, the study level-data for the treatment group are generated by the following bivariate normal distribution:

( m_T 1 , i j_ m_T 2 , i j_ ) ~ B V N ( ( μ_T 1 , j_ μ_T 2 , j_ ) , ∑_T_j__ ) , with ∑_T_j__ = ( σ_C j_^2^ ρ_T_ σ_C j_ σ_T 2 , j_ ρ_T_ σ_C j_ σ_T 2 , j_ σ_T 2 , j_^2^ )

where ρ_T_ is the correlation between pre- and post-treatment measurements in the treatment arm (which in theory can differ from ρ_C_). For our simulations we assessed different values of correlations (based on the empirical component of the project) and assumed that ρ_T_ = ρ_C_.

The effect of treatment^h^ in the j-th study can be written as

h Random allocation to treatment groups implies that the average treatment effect is equal to the difference in the post-treatment values between the treated and control groups. In the absence of confounding, adjustment for the baseline values is useful to improve statistical efficiency. Improvement occurs because the pretreatment value “carries information” about the post-treatment measurement (when the correlation is not exactly zero).

δ_j_ = μ_T 2 , j_ − μ_T 1 , j_ = μ_T 2 , j_ − μ_C 2 , j_

This allows us to write the treatment group generative distribution as:

( m_T 1 , i j_ m_T 2 , i j_ ) ~ B V N ( ( μ_C 1 , j_ μ_C 1 , j_ + δ_j_ ) , ∑_T_j__ )

Note that the total number of individuals in the treatment (N_T_) and control (N_c_) groups does not have to be the same (in the simulation we denote the sample size ratio as SSR = (N_T_)/(N_C_) ). Finally, we were interested in modeling (at least for some simulation scenarios) variability in the treatment effect between studies. To achieve this, we assume that the study-specific treatment effects follow a normal distribution with a common “average” treatment effect (Δ) and some variance (τ^2^): δ_j_ ∼ N(Δ,τ^2^), reflecting standard meta-analytic distributional assumptions. This additional variability can be incorporated in the covariance matrix of the treatment group as follows:

( m_T 1 , i , j_ m_T 1 , i , j_ ) ~ BVN ( ( μ_C 1 , j_ μ_C 1 , j_ + Δ ) , ∑_T_j__ ) and ∑_T_j__ = ( σ_C 1 , j_^2^ ρ_T_ σ_C 1 , j_ σ_T 2 , j_ ρ_T_ σ_C 1 , j_ σ_T 2 , j_ σ_C 1 , j_^2^ + τ^2^ )

The table below summarizes the parameters of the scenarios explored in our simulations. For each scenario we simulated 1000 meta-analyses (i.e., a total of 5000, 10000, and 20000 studies when J was 5, 10, or 20 respectively).

Table A-1 Parameters of the scenarios explored in simulations

Parameter | Explanation | Values used
μ_C_ _1,_ _j_ | Pre-treatment mean in the control group | 0
μ_C_ _2,_ _j_ | Post-treatment mean in the controls; set equal to the pre-treatment variance (μ_C1,j_=μ_C2,j_) | 0
σ_C 1 , j_^2^ | Pre-treatment variance in the controls | 1
σ_C 2 , j_^2^ | Pre-treatment variance in the controls | 1
ρ_C_ | Within-group correlation in the controls | 0 or 0.41 or 0.59 or 0.81 (these values correspond to the presence of no correlation between pre-and post-treatment values, and the 25^th^, 50^th^, and 75^th^ percentile of the empirical correlation distribution, respectively)
μ_T_ _1,_ _j_ | Pre-treatment mean in the treatment group | 0
μ_T_ _2,_ _j_ | Post-treatment mean in the treatment group | Drawn from a distribution; see δ_j_, Δ, and τ^2^
σ_T 1 , j_^2^ | Pre-treatment variance in the treated; set equal to the pretreatment variance in the controls | 1
σ_T 2 , j_^2^ | Post-treatment variance in the treated group; based on the relative magnitude of the variances | Based on VR
VR | Variance ratio, the ratio of the post- to pre-treatment variance in the controls, such that VR = (σ_T 2 , j_^2^)/(σ_T 1 , j_^2^) | 1 or 2
ρ_T_ | Within-group correlation in the treated group; ρ_T_ = ρ_C_ | Same as ρ_C_
N_c_ | Sample size in the controls | 20 or 50 or 100
N_T_ | Sample size in the treated group; set based on the SSR (see below) | Based on the control group sample size; see SSR
SSR | Sample size ratio (treated/controls); SSR = (N_T_)/(N_c_) | 1 or 2
δ_j_ | The treatment effect in each study (δ_j_ = μ_T2,j_ − μ_T1,j_ = μ_T2,j_ − μ_C1,j_); drawn from a distribution of effects (see below) | Drawn from a distribution; see Δ and τ^2^
Δ | The average treatment effect across studies | 0 or 0.1 or 0.5 or 1 (ranges from null effect to a large effect)
τ ^2^ | The between-study variance of the treatment effects | 0 or 0.1 or 0.5 (ranges from no heterogeneity to substantial heterogeneity)
J | The number of studies in each meta-analysis | 5 or 10 or 20 (the vast majority of meta-analyses of clinical trials include less than 20 studies)
Number of simulation scenarios | The product of the number of values explored for each parameter in the simulation | 1728