# References

1 Committee on Quality of Health Care in America, Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC. The National Academies Press. 2001.
2 Shekelle PG, Pronovost PJ, Wachter RM, et al. Assessing the Evidence for Context-Sensitive Effectiveness and Safety of Patient Safety Practices: Developing Criteria. (Prepared under Contract No. 290-2009-0001C.) AHRQ Publication No. 11-0006-EF. Rockville, MD. Agency for Health Care Research and Quality. December. 2010. www.ahrq.gov/research/findings/final-reports/contextsensitive/context.pdf.
3 Damschroder L, Aron D, Keith R, et al. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implement Sci. 2009;4(1):50. [pmid: 19664226].
4 Gerring J. What makes a concept good? A critical framework for understanding concept formation in the social sciences. Polity. Spring. 1999;31(3):357-93.
5 Proctor E, Silmere H, Raghavan R, et al. Outcomes for implementation research: conceptual distinctions, measurement challenges, and research agenda. Adm Policy Ment Health. Mar. 2011;38(2):65-76. [pmid: 20957426].
6 Foy R, Ovretveit J, Shekelle PG, et al. The role of theory in research to develop and evaluate the implementation of patient safety practices. BMJ Qual Saf. May. 2011;20(5):453-9. [pmid: 21317181].
7 Clegg CW. Sociotechnical principles for system design. Appl Ergon. 2000;31:463-77. [pmid: 11059460].
8 Stetler CB, Damschroder LJ, Helfrich CD, et al. A Guide for applying a revised version of the PARIHS framework for implementation. Implement Sci. 2011;6:99. [pmid: 21878092].
9 Gustafson DH, Sainfort F, Eichler M, et al. Developing and testing a model to predict outcomes of organizational change. Health Serv Res. Apr. 2003;38(2):751-76. [pmid: 12785571].
10 Harrison MI, Kimani J. Building capacity for a transformation initiative: system redesign at Denver Health. Health Care Manage Rev. Jan-Mar. 2009;34(1):42-53. [pmid: 19104263].
11 Kaplan HC, Provost LP, Froehle CM, et al. The Model for Understanding Success in Quality (MUSIQ): building a theory of context in healthcare quality improvement. BMJ Qual Saf. Jan. 2012;21(1):13-20. [pmid: 21835762].
12 Nutting PA, Crabtree BF, Miller WL, et al. Transforming physician practices to patient-centered medical homes: lessons from the national demonstration project. Health Aff (Millwood). Mar. 2011;30(3):439-45. [pmid: 21383361].
13 Henriksen K, Joseph A, Zayas-Caban T. The human factors of home health care: a conceptual model for examining safety and quality concerns. J Patient Saf. Dec. 2009;5(4):229-36. [pmid: 22130216].
14 Carayon P, Schoofs Hundt A, Karsh BT, et al. Work system design for patient safety: the SEIPS model. Qual Saf Health Care. Dec. Suppl 1. 2006;15:i50-8. [pmid: 17142610].
15 Kanter R. Men and Women of the Corporation. 2nd ed. New York. Basic Books. 1977.
16 Helfrich CD, Li YF, Sharp ND, et al. Organizational readiness to change assessment (ORCA): development of an instrument based on the Promoting Action on Research in Health Services (PARIHS) framework. Implement Sci. 2009;4:38. [pmid: 19594942].
17 Greenhalgh T, Robert G, Macfarlane F, et al. Diffusion of innovations in service organizations: systematic review and recommendations. Milbank Q. 2004;82(4):581-629. [pmid: 15595944].
18 Rogers EM. Diffusion of Innovations. 5th ed. New York. Free Press. 2003.
19 Locock L, Dopson S, Chambers D, et al. Understanding the role of opinion leaders in improving clinical effectiveness. Soc Sci Med. Sep. 2001;53(6):745-57. [pmid: 11511050].
20 Burston S, Chaboyer W, Wallis M, et al. A discussion of approaches to transforming care: contemporary strategies to improve patient safety. J Adv Nurs. Nov. 2011;67(11):2488-95. [pmid: 21627678].
21 Murray E, Burns J, May C, et al. Why is it difficult to implement e-health initiatives? A qualitative study. Implement Sci. 2011;6:6. [pmid: 21244714].
22 Glasgow R, Boles S, Vogt T. Reach Effectiveness Adoption Implementation Maintenance-RE-AIM Framework. Blacksburg, VA. Human Nutrition, Foods and Exercise, College of Agriculture and Life Sciences, Virginia Polytechnic Institute and State University. 2012. www.re-aim.org/about_re-aim/what_is_re-aim/index.html. July 16, 2012.
23 National Committee for Quality Assurance. NCQA's Patient-Centered Medical Home (PCMH). 2011. www.ncqa.org/Portals/0/Programs/Recognition/PCMH_2011_Overview_5.2.pdf. July 11, 2013.
24 Agency for Healthcare Research and Quality. Patient Centered Medical Home Resource Center. Rockville, MD. Agency for Healthcare Research and Quality. 2012. http://pcmh.ahrq.gov/portal/server.pt/community/pcmh__home/1483/pcmh_home_v2. June 19, 2013.
25 James B, Bayley KB. Cost of Poor Quality or Waste in Integrated Delivery System Settings. Final Report. AHRQ Publication No. 08-0096-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2006. www.ahrq.gov/research/findings/final-reports/costpqids/index.html.
26 McCarthy EL. Physician office productivity improvement through operations analysis and process redesign. J Ambul Care Manage. Oct. 2002;25(4):37-52. [pmid: 12371018].
27 Parchman ML, Pugh JA, Culler SD, et al. A group randomized trial of a complexity-based organizational intervention to improve risk factors for diabetes complications in primary care settings: study protocol. Implement Sci. 2008;3:15. [pmid: 18321386].
28 Driscoll DL, Hiratsuka V, Johnston JM, et al. Process and outcomes of patient-centered medical care with Alaska Native people at Southcentral Foundation. Ann Fam Med. May-Jun. Suppl 1. 2013;11:S41-9. [pmid: 23690385].
29 Coleman EA. The Care Transitions Program. Aurora, CO. Division of Health Care Policy and Research, University of Colorado Denver. www.caretransitions.org. February 8, 2013.
30 Coleman EA, Boult C, American Geriatrics Society Health Care Systems Committee. Improving the quality of transitional care for persons with complex care needs. J Am Geriatr Soc. Apr. 2003;51(4):556-7. [pmid: 12657079].
31 Rennke S, Shoeb MH, Nguyen OK, et al., et al. Chapter 37. Interventions to improve care transitions at hospital discharge. Shekelle PG, Wachter RM, Pronovost RH, editors. Making Health Care Safer II: An Updated Critical Analysis of the Evidence for Patient Safety Practices. Evidence Reports/Technology Assessments, No. 211. Prepared by the Southern California-RAND Evidence-based Practice Center under Contract No. Rockville, MD. 2013.
32 Robert Wood Johnson Foundation. Care Across Settings: Challenges, Successes and Opportunities. 2013. www.rwjf.org/content/dam/farm/reports/issue_briefs/2013/rwjf404875. June 11 2013.
33 Begun JW, Zimmerman B, Dooley K. Health care organizations as complex adaptive systems. Mick SM, Wyttenbach M, editors. Advances in Health Care Organization Theory. San Francisco. Jossey-Bass. 2003:253-88.
34 Chamberlain P, Brown CH, Saldana L. Observational measure of implementation progress in community based settings: The Stages of implementation completion (SIC). Implement Sci. 2011;6:116. [pmid: 21974914].