# Process Redesign Framework

## Overview^b^ b Because the three frameworks are described in stand-alone chapters, the Overview and Organization sections are similar across the chapters.

Process redesign (PR) involves changing the way care is delivered by “conceptualizing, mapping, refining, and continuing to improve the many processes of healthcare.” Further, redesign may “challenge existing practices, data structures, roles, and management practices, and it results in continuous change.”1 The focus of our work was to develop an integrative framework that would guide implementation research on PR for improved efficiency and reduced costs: the PR Framework. A few examples of these kinds of interventions include changes to an office or clinic workflow to allow administrative tasks to be carried out more easily and with less time, the introduction of new equipment or technology to improve clinical procedures, or streamlining billing procedures.

The purpose of this PR Framework is to guide research and evaluation of PR implementation within a broad range of organizational settings. The primary users of this framework are investigators and practitioners who wish to understand why implementation succeeds or fails and whether the PR intervention or its components can be replicated and scaled to other settings. Investigators can apply the PR Framework to a whole intervention with various distinct parts or to one or more of those parts.

This chapter is organized into six sections. The first section briefly describes the domains of the PR Framework. It is followed by a discussion of the most noteworthy changes we made from the Consolidated Framework for Implementation Research (CFIR). The PR Framework is next presented in two forms, a graphic followed by a full explication of the domains, constructs, and subconstructs in Tables 2 through 8. The How To Use section gives users a step-by-step roadmap for approaching the multiple and complex dimensions of the framework. This chapter concludes with a case study of a PR implementation that applies the roadmap. See the Glossary for important terms.

Table 2 Process Redesign Framework—Intervention Characteristics

Construct | Description | Examples
A. Vision and change strategy (NEW) | The proposed changes envisioned by the PR and the theory of change: how the intervention is supposed to work, what it is meant to achieve or do.6 May be explicated in logic models, goals, outcomes, and performance measures. | According to sociotechnical theory, engaging end-users in the design of the process will result in greater utility and adoption.7
B. Targeted groups | The staff and others (vendors, patients) who will be impacted by the intervention. | —
C. Intervention source | Identifying who (which individuals or groups) originated the PR initiative and/or from which source the components of the initiative were derived. | —
D. Evidence strength and quality | Target group and other stakeholders' perceptions of the quality and validity of evidence supporting the belief that the PR will have the desired outcomes.8 | Peer-reviewed published literature; Institute of Medicine Consensus Study Reports.
E. Relative advantage | Target group and other stakeholders' perception of the advantage of the PR instead of other possible interventions or maintaining the status quo.7 | —
F. Adaptability | Target group and other stakeholders' perception of the degree to which PR strategies, techniques, and practices can be adapted to local needs. | —
G. Feasibility (NEW) | Target group and other stakeholders' perception of the extent to which the PR can be successfully used or carried out within a given organization or setting. | —
H. Trialability | Target group and other stakeholders' perception of the ability to test and refine components of the PR on a small scale in the organization. | —
I. Complexity | Target group and other stakeholders' perception of duration, scope, centrality, and intricacy, and number of steps required to implement. | —
J. Compatibility (NEW) | Target group and other stakeholders' perceptions regarding the alignment of values and norms attached to PR with those of the practice or organization. | —
K. Radicalness (NEW) | Target group and other stakeholders' perception of the degree of difference between the change envisioned and the current state.9 | —
L. User control (NEW) | The degree to which the intervention relies on the end-users' authority/skill to implement the PR on their own vs. reliance on experts. | Implementation of Lean requires use of consultants trained in Lean methods.
M. Workflows (NEW) | Tasks and workflows, including interdependencies between them that are the focus of the change strategy or that will be affected by it.7 | —
N. Task /process standardization (NEW) | Degree to which the PR seeks to standardize selected tasks and/or processes that require iterative consultation. | —
O. History (NEW) | Experiences with similar interventions within the setting and within the target population. | The maturity, breadth, and depth of quality improvement processes used within an integrated physician network to increase the efficiency of referral appointments.10,11

Note: PR = process redesign.

Table 3 Process Redesign Framework—Outer Setting

Construct | Description | Examples
A. External networks | Degree to which an organization is networked with other external organizations that are engaged in similar types of PR development activities. (Termed “cosmopolitanism” in the CFIR.) | —
B. External pressure | Pressure emanating from outside the organization to implement a PR intervention. | Key peer or competing organizations have already implemented PR; there is competitive pressure to secure a better share of the market.
C. External policy and incentives/disincentives | Laws and regulations (governmental or other central entity), recommendations and guidelines, and payment schemes that affect the decision to adopt or abandon the PR. | —
D. Technological environment (NEW) | Technological trends and movements, and the availability of technological innovations that may affect the intervention and its context. | Software product trends, health information exchanges, cloud computing, social media mobile applications.

Note: CFIR = Consolidated Framework for Implementation Research; PR = process redesign.

Table 4 Process Redesign Framework—Inner Setting

Construct | Description | Examples
A. Structural characteristics | Social architecture; age; maturity; size; mix of occupations of team, unit, organization, or system; and the employment status of physicians. | —
B. Team and network characteristics | Influence, breadth, depth, and role diversity of teams and networks engaged in the PR.11 | —
B1. Teams, networks, and communications | Nature and quality of teams and social networks; formal/informal communication and information exchange within an organization or between organizations. | —
B2. Team and network self-organization | Capacity to arrange and organize for a defined (nonrandom) purpose without external pressure or mandate. | —
C. Culture | Norms, values, and beliefs within a team, unit, or practice that affect views of PR and its implementation. | —
D. Implementation climate | Capacity or reserve12 for change and the shared receptivity of involved individuals to the intervention. | —
D1. Tension for change | Degree to which stakeholders perceive the current situation as intolerable or needing change. | —
D2. Mandate | Whether compliance with the PR initiative is expected. | —
D3. Accountability | Whether entities are subject to tangible consequences for noncompliance. | —
D4. Relative priority | Individuals' shared perception of the importance of the PR implementation within the organization. | —
D5. Organizational incentives | Extrinsic incentives offered to adopt PR. | Gain-sharing awards, promotions, increased stature, or respect.
D6. Learning climate | The organization's willingness to promote trial and error, test new methods, and innovate.11 | Routine and structured quality improvement activities.
E. Readiness for implementation | Tangible and immediate indicators of organizational commitment to its decision to implement PR. | —
E1. Leadership commitment | Degree of commitment, involvement, and accountability of leaders and managers to quality and safety improvement and the PR initiative. | —
E2. Staff commitment (NEW) | Degree of commitment, involvement, and accountability of physicians, nurses, and other staff to efficiency and waste reduction and to the PR specifically. | Provider involvement in setting and monitoring efficiency targets.
F. Access to information, training, education | Ease of access for staff to digestible, applicable information and knowledge about PR. Resources dedicated to training and education. | Online training tools, time given for training and education, funding for training.
G. IT and HIT resources (NEW) | Technological infrastructure in place to support electronic information management and redesign of patient care. | —
G1. HIT systems (NEW) | Electronic information management infrastructure and technologies available to clinicians to manage patient care, data, and communications. | Decision support tools, e-prescribing, electronic health records.
G2. IT systems (NEW) | Technological systems and capabilities to support PR. | Server space, bandwidth, interoperability, health information exchange.
G3. Human factors (NEW) | Features of the physical and technical environment of the practice that determine the use, accessibility, and acceptability of technology in patient care.13 | Repositioning the blood pressure station to create more rapid intake flow.
H. Physical space and equipment (NEW) | Physical space and equipment dedicated to or impacted by the PR intervention.14 | —
I. Staff time (NEW) | Time dedicated to implement the PR intervention. | Paid time given to implementation staff to attend trainings, and adjust and adapt to new processes.

Note: HIT = health information technology; IT = information technology; PR = process redesign.

Table 5 Process Redesign Framework—Characteristics of Individuals and Teams

Construct | Description | Examples
A. Knowledge and beliefs | Views regarding the PR, as well as familiarity with facts, truths, and principles related to the intervention. | —
B. Skills and competencies (NEW) | Degree of relevant subject matter expertise, skills, and competencies within the implementing team, unit, and organization. | —
C. Role (NEW) | Individual's or team's role and responsibilities, and extent of multiple or shared roles. | —
D. Authority (NEW) | Perceived and actual degree of authority to make decisions and act autonomously.15 | —
E. Self-efficacy | Confidence in the capacity to execute the courses of action necessary to achieve PR goals. | —
F. Collective efficacy (NEW) | Conviction of individuals and teams involved that the PR transformation can be carried out in cooperation with others.16 | —
G. Stage of change | Phase an individual or team is in; characterizes progress toward skilled, enthusiastic, and sustained application of PR strategies. | —
H. Identification with organization | How individuals or teams perceive the organization, and their relationship and degree of attachment with the organization. | —
I. Patient needs and resources (NEW) | Patient priorities for health and health care, and the social and economic capital to address those priorities. | —
J. Other personal attributes | Other personal traits not captured elsewhere. | Tolerance of ambiguity, intellectual ability, motivation, values, competence, capacity, learning style.

Note: PR = process redesign.

Table 6 Process Redesign Framework—Process of Implementation

Construct | Description | Examples
A. Planning | Degree to which implementation steps or tasks are developed in advance and take into account various scenarios; the quality of those schemes or methods. | Contingency planning.
A1. Assessing (NEW) | Formal assessment of the problem or condition to be changed, including needs of users and barriers and facilitators of change. | Root cause analysis.
A2. Goal-setting | Written goals, objectives, benchmarks, and timelines for PR activities, and their feasibility and adequacy. | —
A3. Feedback | Procedures used to provide feedback to stakeholders and their adequacy. | —
B. Acquiring and allocating resources (NEW ) | Staff time, space, equipment, and other resources dedicated to implementing the PR; the adequacy of those allocations. | —
C. Process ownership (NEW) | The diversity of practice roles involved in processes of implementation; authority and accountability for these activities. | —
D. Practice roles | Roles of those involved in the decision to adopt, execute, and facilitate the intervention. | —
D1. Organizational leaders (NEW) | Managers and others with the authority to dedicate resources and make decisions to maintain or abandon the implementation. | —
D2. Opinion leaders | Individuals who influence (positively or negatively) the attitudes and beliefs of their colleagues.17,18 | Experts and peers.19
D3. Implementation leaders | Individuals formally appointed with responsibility for implementing the PR. | Project manager, team leader, project coordinator.
D4. Champions | Individuals who dedicate themselves to galvanizing and maintaining support for the PR and overcoming indifference or resistance. | —
D5. External change agents | Individuals outside the organization who can facilitate or undermine decisions about PR adoption and implementation. | Individuals from health plans, other health care systems, consultants, policymakers.
D6. Facilitator (NEW) | A formally appointed role that provides reflective, empathetic, and interactive counsel. | Experts who model and teach new skills and practices.16
D7. Frontline staff (NEW) | Administrative staff and providers (within and outside the organization) who will implement the PR or be impacted by it. | —
D8. Patients and other stakeholders (NEW) | Individuals and their caregivers who are impacted by the PR. | —
E. Engaging | Processes involved in attracting and involving appropriate individuals in the implementation and use of the intervention.10 | Capitalizing on relationships between leaders and frontline staff.
F. Executing | Manner in which those involved carry out and accomplish the implementation according to plan; the role and authority to execute.15 | —
F1. Decisionmaking (NEW) | The frequency, duration and timing of the activities involved in making decisions about the intervention.11 The directionality of those activities.20 | Decisions made top down vs. bottom up.
F2. Staging and iteration (NEW) | Whether the implementation is carried out in incremental steps, refined iteratively, or implemented in its entirety within a specified period. | —
F3. Facilitating and coaching | Use of experts to teach new processes, model best practices, and develop solutions; the structure, formality, and adequacy of these activities. | —
G. Reflecting and evaluating | Quantitative and qualitative feedback on the quality of the implementation process21^—^“reflexive monitoring” and the degree to which it is attained. | Project monitoring, systematic feedback processes.
G1. Measurement capability and data availability (NEW) | Availability of data and capacity to use them for monitoring, evaluation, and process improvement. Includes measurement differences between organizations; sharing; accountability for collection, documentation, and analysis; and timeliness.

Note: PR = process redesign.

Table 7 Process Redesign Framework—Measures of Implementation (new domain)

Construct | Description | Examples
A. Acceptability (NEW)2 | Degree to which PR goals, strategies, tactics, and specific activities are agreeable, palatable, or satisfactory. | —
B. Adoption/abandonment (NEW)2 | Intention, initial decision, or action to employ or cease PR. | —
C. Appropriateness (NEW)2 | Suitability of the PR intervention to the specific issues or problems to be addressed. | —
D. Intervention cost (NEW)2 | Costs of the PR interventions and costs associated with implementation, ongoing maintenance costs, and opportunity costs. | Investment costs for training, staffing, and IT updates.
E. Fidelity (NEW)2 | Degree to which PR was implemented as intended by those who developed and/or introduced it to the organization. | —
F. Reach (NEW) | Absolute number, proportion, and representativeness of entities willing to participate in the PR.22 | —
F1. Reach within the population (NEW) | Number of patients exposed to or participating in the PR intervention. | —
F2. Reach within the organization (NEW) | Absolute number, proportion, and representativeness of individuals and subcomponents within an organizational setting exposed to or participating in the PR.22 | Percentage of practices within a network that adopt open scheduling.
G. Penetration (NEW)2 | Depth of integration of a process design implementation within a service setting and its subsystems. | Among practices with e-prescribing, the percentage of patients who receive e-prescriptions.
H. Replicability (NEW) | Degree to which the PR implementation process and outcomes can be reproduced beyond the adopting site or setting. | —
I. Sustainability (NEW)2 | Degree to which changes resulting from PR are maintained or institutionalized within a service setting. | —
J. Evolvability (NEW) | Degree to which the change is sustained through adaptation and refinement. | —

Note: IT = information technology; PR = process redesign.

Table 8 Process Redesign Framework—Outcomes (new domain)

Construct | Description | Examples
A. Patient experience (NEW) | Impact on patient experiences with care, including satisfaction with care and patient-provider interactions at the same or lower cost.21 | —
B. Provider experience (NEW) | Effect(s) on a provider's burden of effort and quality of work life, communication, and interactions with patients and colleagues.21 | —
C. Accessible (NEW) | Extent to which PR delivers access to routine/urgent care and clinical advice during and after business hours, provides electronic access.23 | —
D Quality (NEW) | Extent to which PR shows an ongoing commitment to high quality through the use of performance measurement, evidence-based strategies, etc.24 | —
E. Safety (NEW)3 | Extent to which the intervention contributes to providing safe care for patients; avoiding injuries. | —
F. Effectiveness (NEW)3 | Extent to which the intervention contributes to providing services to all who could benefit, without providing services to those who would not. | —
G. Timeliness (NEW)3 | Extent to which the intervention contributes to reducing wait times and delays, both for those who provide care and those who receive it. | —
H. Efficiency (NEW) | Improvement in an outcome without added resource inputs or with less resources/cost than previously required.25 | Reduction in equipment, supplies, provider time, or patient time (without harm to quality).
I. Productivity (NEW) | Degree to which the intervention results in greater output of a service or good in the same or less amount of time. | Number of tests processed per hour.
J. Equitable (NEW) | Extent to which disparities in care are reduced or eradicated.1 | —
K. Health care utilization (NEW) | Changes in the frequency, type, timing, and duration of use of health care services.1 | —
L. Cost effects/impact (NEW) | Cost impact (summative or incremental) to the unit or organization resulting from changes in health care utilization and efficiency. Fixed and variable costs; offsets of the cost of implementation. | —
M. Perceived value (NEW) | Perceived worth, utility, and importance of the benefits of efficiency and cost saving to the organization. | —
N. Unintended consequences (NEW) | Emergent, interim, or longer term outcomes that were unanticipated and usually not desired. | —

Note: PR = process redesign.

## Organization of the Process Redesign Framework

Tables 2 through 8 show the entire PR Framework that we adapted from the CFIR.3 The content is organized into seven domains that represent families of constructs we subdivided into more precise subconstructs. These elements are summarized with their definitions in the first columns of the tables; those elements labeled “new” were not part of the original CFIR. The PR Framework domains, adapted from the CFIR, are —

- Intervention Characteristics: The characteristics and features of the intervention being implemented into a particular organization or organizations, including core components (the essential and indispensable elements of the intervention itself). These may be fixed or mutable attributes; they are considered and assessed prior to implementation and influence adoption decisions.
- Outer Setting: Includes the economic, political, and social context within which an organization resides.
- Inner Setting: Tangible and intangible manifestation of characteristics of the organizations involved in the intervention, including structural characteristics, networks and communications, culture, climate, and readiness, which all interrelate and influence implementation.
- Characteristics of Individuals and Teams: The individuals (as carriers of cultural, organizational, professional, and individual mindsets, norms, interests, and affiliations) involved with the intervention and/or implementation process. Includes patients and caregivers.
- Process of Implementation: Refers here to the course of actions (e.g., planning, engaging, and reflecting) to achieve individual- and organizational-level use of the intervention as designed.
- Measures of Implementation: Refer to what Proctor et al.5 call “implementation outcomes”; they are intermediary outcomes that describe how well the implementation was carried out and the prospects for sustainability.
- Outcomes: The results of the PR implementation, defined as the targets of the PR intervention.

The PR Framework provides a comprehensive menu of contextual domains and constructs. Users of the framework may find it useful to refine the subconstructs even further for specific research purposes. Researchers could use these frameworks to define and review the range of potentially relevant concepts and variables as they prepare an implementation study. Additionally, they may engage in prestudy to determine which constructs are likely to be most useful. During their research, they may refine their selection of constructs and construct specifications in response to data that emerge from the field or in response to changes in the intervention process and context that take place during the life course of the intervention.

## Modifications in the Process Redesign Framework

The CFIR served as the foundation for the PR Framework. In addition, the PR and patient-centered medical home (PCMH) Frameworks were developed simultaneously, and therefore additions to one framework resulted in similar additions to the other when appropriate. All construct and subconstruct additions are noted in Table B in the Executive Summary and Table 25 in the Discussion. Descriptions and examples of the original CFIR have been modified to enhance their resonance to PR researchers and evaluators. Below, we briefly list some of the constructs, by domain, that were added to the PR Framework based on the input of the PR Technical Expert Panel or our review of the PR literature. For definitions of these constructs, we direct the reader to the PR Framework tables that follow.

- Intervention Characteristics: The PR Framework includes the following new constructs reflecting characteristics of a PR intervention, which often focuses on changing a process involving technology or workflow: vision and change strategy, feasibility, compatibility, radicalness, user control, workflows, and task/process standardization.
- Outer Setting: Technological environment reflects the importance of technological trends and updates in the development and implementation of a PR intervention.
- Inner Setting: New constructs related to features of the inner setting that may impact the PR implementation include staff commitment (a subconstruct under readiness for implementation), information technology (IT) and health information technology (HIT) resources, human factors, physical space and equipment, and staff time.
- Characteristics of Individuals and Teams: New constructs include skills and competencies that add additional dimensions beyond knowledge and beliefs.
- Process of Implementation: We defined the executing construct with more detail, adding staging and iteration as a subconstruct.
- Measures of Implementation: This is a new domain. The PR Framework made a few modifications to those described in Proctor et al.5 To adoption, we added abandonment, since the decision to stop an implementation can be as important to consider in implementation research as the decision to begin an implementation. Feasibility was moved to Intervention Characteristics, as it is an attribute of the intervention to be considered in the decision to implement, but it can change over the course of implementation. Replicability in process redesign is often an explicit goal; an intervention must be successful not only in one setting but multiple settings. Cost was further clarified by adding implementation to distinguish it from other cost outcomes.
- Outcomes: In order to provide users with a comprehensive list of outcomes related to PR, we included the following constructs: cost effects/impact, perceived value, and unintended consequences. Furthermore, we capture the aims outlined by the Institute of Medicine (IOM) in its seminal 2001 report1 by including the following outcomes: safety, effectiveness, timeliness, efficiency, and equitable (originally termed equity in the IOM report).

## Graphic Representation of the Process Redesign Framework

Figure 2 shows the relationships of five of the domains to measures of implementation success and various PR outcomes. On the left side of the figure is an inner circle with four domains: Intervention Characteristics, Individual/Team Characteristics, Inner Setting, and Process of Implementation. Surrounding this inner circle is an outer ring named the Outer Setting that may influence these four domains. An arrow to the right of the inner and outer circles points to the Measures of Implementation, which influence Outcomes.

Figure 2 Framework for Implementation Research on Process Redesign

Figure 2 is a graphic representing the relationship between the domains of the Process Redesign Framework. On the left side of the graphic, the following four domains are shown as four equal quadrants of a circle: Starting from the top left quandrant and proceeding clockwise these domains are: intervention characteristics, individual/team characteristics, inner setting and process of implementation.. This circle is surrounded by another circle that represents the outer setting domain. These two concentric circles feed into an arrow-shaped box to the right labeled Measures of Implementation. The Measures of Implementation box feeds into an arrow-shaped box on the far right of the figure labeled Outcomes.

## How To Use the Process Redesign Framework

The flowchart in Figure 3 presents step-by-step guidance on how the PR Framework may be used. The flowchart presents a series of questions, and each set of questions is tied to a particular domain in the framework (Tables 2 through 8). As these questions are considered, the user should refer to the appropriate domain in the framework table to see which constructs are relevant. For example, Step 1 corresponds to the Intervention Characteristics domain; as users consider the various issues related to this domain, they should refer to the framework to choose those constructs relevant to them.

Figure 3 How to use the Process Redesign Framework

Figure 3 is a flowchart with seven steps that correspond to the seven domains in theProcess Redesign Framework. The seven steps are aligned vertically in boxes, starting with step 1 at the top of the figure and ending with step 7 at the bottom of the figure. Each step has an arrow pointing down to the next step. The first step in the flowchart is to define the intervention. The second step is to define the outer setting. The third step is to define the inner setting. The fourth step is to define the characteristics of the individuals and teams involved in the intervention. The fifth step is to define the process of implementation. The sixth step is to define the measures of implementation. The seventh and final step is to define the outcomes. The right-hand side of each step includes a series of questions for users to consider in completing the step.

As mentioned, the framework does not prescribe which constructs must be selected due to the diversity of research objectives and to variations between different PR interventions. The frameworks are designed to be a practical tool for research and evaluation, and it would be unfeasible to include all or even most of the constructs described. While following this step-by-step process of using the framework, we recommend that users of the framework select qualities, features, or characteristics that are closely tied to intervention outcomes and aligned to the goal, questions, theory, or model guiding the research or evaluation. Doing so will help the user prioritize the constructs, remain focused on the essential aims of the investigation, and keep the number of constructs to a manageable size.

## Content of the Process Redesign Framework

We present the PR Framework in Tables 2 through 8 with brief definitions of the constructs and subconstructs, and examples. Constructs labeled “new” are additions to the original CFIR.3 Based on Technical Expert Panel input, we added clarifying examples for those constructs and subconstructs that were unclear or complex. Each construct or subconstruct is independent and should be applied, as appropriate, to the research questions and objectives.

## Applying the Process Redesign Framework: A Case Study

To illustrate how the PR Framework may be applied, we present below a brief case study. It is based on a published case study by E. L. McCarthy, “Physician office productivity improvement through operations analysis and process redesign.”26

### Practice Scheduling Redesign Case Study

Eleven hospital-owned physician practices connected with a multihospital system implemented a process redesign of key scheduling and prescription filling processes. These were multiprovider practices engaged in a mix of primary care specialties, including pediatrics, family, and internal medicine practices. These physician practices had large patient panels of approximately 195,000 patient encounters per year. The overall focus of the process redesign was on improving patient access to timely appointments (offices were booked 3 to 5 months in advance) and improving systems for faster throughput. The scope of the project included a step-by-step analysis of all the workflow processes in each practice. Here, we focus on the following processes:

- Patient appointment scheduling
- Physician/patient scheduling templates
- Pharmacy refills and prescriptions
- Patient check-in

The process redesign involved mapping individual functions at each practice and then comparing them with other offices to identify process improvements that could be replicated widely across the network. These process improvements included—

- Patient appointment scheduling. Wave scheduling blended routine office visits, physicals, and sick visits so as to eliminate periods of extremely high and low activity. Available time slots were thus maximized and patient throughput enhanced.
- Physician/patient scheduling templates. The scheduling templates for each specialty, with the same number and type of office visits scheduled in any given hour, were standardized. This change was implemented concurrently with the wave scheduling.
- Pharmacy refills and prescriptions. The existing manual telephone call process to place prescription orders was replaced with a single prescription form for multiple patients that was faxed to each pharmacy.
- Patient check-in. A standard best-practice list for check-in functions was developed that included the printing of encounter forms and charts, collection of demographic and insurance information, and collection of copayments.

### Applying the Process Redesign Framework

Below, we walk through the how-to-use flowchart detailed in Figure 3. For illustrative purposes, we examine this study at a high level with a short list of constructs. In real-world implementations, many more constructs may be relevant. Researchers will have to select a workable subset of potentially relevant constructs. This selection will likely be influenced by previous experience and research, current research aims, and practical considerations.

#### Step 1 Define the Intervention

In this step, the user of the framework examines the first major domain in the PR Framework: Intervention Characteristics.

- What is the intervention designed to achieve?
  The PR intervention strategy in this case study consists of a step-by-step analysis and operational improvement of scheduling, prescription filling, and check-in processes at each physician practice under consideration to improve patient access and throughput. The PR techniques employed include:
  a. Mapping individual functions performed at each office, assessing their efficiency, and comparing levels of efficiency across offices;
  b. Identifying best practices; and
  c. Streamlining procedures to implement best practices at all offices.
  In addition, the user examines the following issues, while selecting relevant constructs from the domain.
- What are the features of the intervention?
  Here, the user considers the details of the various intervention steps mentioned above (a, b, and c), such as the steps involved in mapping the criteria for a best practice and methods for streamlining. Relevant constructs that may be used include feasibility, trialability, and complexity. See Table 2 for definitions of constructs.
- Who is the intended target group?
  Relevant constructs that may be used include targeted groups and workflows, including interdependencies. See Table 2.

#### Step 2 Define the Outer Setting

- What components of the environment will impact the implementation?
  Here, the user examines various relevant outer setting constructs that may include, for example, external pressure (e.g., from competing hospital systems that have successfully implemented similar PR interventions) and technological environment (e.g., new software that facilitates faster processing of patients at check-in). See Table 3.

#### Step 3 Define the Inner Setting

- What components of structure and process within the inner setting will impact the implementation?
  These may be tangible and intangible manifestations of structural characteristics, networks and communications, culture, climate, readiness, and so on. Relevant constructs here include culture (e.g., how staff will adapt to changing longstanding pharmacy refill processes and whether there will be significant pushback from staff) and knowledge (e.g., knowledge gained by involved staff who have experience with similar interventions in the past). See Table 4.

#### Step 4 Define the Characteristics of the Individuals/Teams Involved

- What are the characteristics of individuals (or teams) and patients that will help in making the PR intervention and/or implementation successful?
  A relevant construct may include skills and competences (e.g., whether staff members have the skills needed to effectively conduct wave scheduling or require additional training). Patient needs and resources might include access to transit, ability to make appointments during work and school hours, and need for translation services. See Table 5.

#### Step 5 Define the Processes Required To Achieve Desired Level of Use

- What are the implementation processes that are required to achieve individual- and organizational-level use of the intervention?
  Relevant constructs to consider may include planning (e.g., whether the rollout has clear milestones, timelines, and dedicated staff accountable for actions) and staging and iteration (e.g., whether changes are being introduced slowly and refined in one site before scaling to another site or are being implemented across the board with each site responsible for adapting to local conditions). See Table 6. This step does not cover how completely an intervention was used; this concept is covered under the Measures of Implementation domain.

#### Step 6 Define Successful Implementation

- What are the attributes of the implementation process that demonstrate it was carried out well and can be replicated, scaled, and sustained?
  Constructs here include acceptability (e.g., whether staff members believe that the goals of the intervention are acceptable), intervention cost (e.g., the financial costs of the implementation), reach (percentage of offices that use wave scheduling 6 months after implementation), and penetration (proportion of staff within each practice using the wave scheduling). See Table 7.

#### Step 7 Define the Outcomes

- What are the specific measurable outcomes that will result from the intervention?
  Relevant constructs, representing outcomes, may be accessibility, patient experience, provider experience, timeliness, and efficiency. The user is encouraged to revisit previous domains to ensure that the outcomes selected in this step are supported by the intervention. In particular, the user would tie these outcomes back to the goals of the intervention (improving patient access and throughput), listed under the first step. See Table 8.

[underlined: Note:] Constructs in the PR Framework, because they represent the components of a complex system intervention, can be explored at multiple levels (i.e., at the individual, team, or organizational level). In Table 9, we show how a handful of constructs applicable to this case study are relevant across multiple organizational levels. For brevity, we show only three levels, but other levels may be relevant, depending on the scenario. For example, in some cases, a “unit” might be a level that comprises groups of “teams.” However the levels may be defined, the important aspect is to ensure that users of the framework appreciate that each construct may (and in most cases should) be applied at various levels, and not just at one.

Table 9 Example of application of Process Redesign Framework constructs to diverse levels of analysis by organizational level

Construct | Individual | Team | Organization
External pressure | N/A | N/A | ✓
Workflows | N/A | ✓ | ✓
Planning | N/A | ✓ | ✓
Accessibility | ✓ | N/A | N/A

Note: N/A = not added.