# Patient-Centered Medical Home Framework

## Overview^c^ c Because the three frameworks are described in stand-alone chapters, the Overview and Organization sections are similar across the chapters.

A patient-centered medical home (PCMH), as defined by the Agency for Healthcare Research and Quality, is an organizational model of primary care with the following functions and attributes: comprehensive, patient centered, coordinated, accessible, high quality,24 and safe. Achieving these functions and attributes requires a complex set of changes and innovations that go well beyond the boundaries of the practice setting and include provider and hospital networks, insurers, and Federal agencies. Examples of PCMH interventions within the practice setting include team-based care, the use of facilitation and coaching to develop skills, and disease registries that allow the provider to see patients not just as individuals but as part of a larger population with common needs and concerns.

The purpose of the PCMH Framework is to guide research and evaluation of PCMH implementation within a broad range of organizational settings. The primary users of this framework are investigators and practitioners who wish to understand why PCMH implementation succeeds or fails and whether the PCMH intervention or its components can be replicated and scaled to other settings. The PCMH Framework is intended to guide users in the design of a study or evaluation project. Some practitioners, because of the comprehensiveness of the PCMH Framework, may also find it useful for intervention design and continuous quality improvement. Investigators can apply the PCMH Framework to a whole intervention with various distinct parts or to one or more of those parts.

This chapter is organized into six sections. The first section briefly describes the domains of the PCMH Framework. It is followed by a discussion of the most noteworthy changes we made. The PCMH Framework is next presented in two forms, a graphic followed by a full explication of the domains, constructs, and subconstructs in Tables 10 through 16. The How To Use section gives users a step-by-step roadmap for approaching the multiple and complex dimensions of the PCMH Framework. This chapter concludes with an application of the roadmap to a PCMH case study. See the Glossary for important terms.

Table 10 Patient-Centered Medical Home Framework—Intervention Characteristics

Construct | Description | Examples
A. Vision and change strategy (NEW) | The proposed changes envisioned by the PCMH and the theory of change: how the intervention is supposed to work, what it is meant to achieve or do.6 May be explicated in logic models, goals, outcomes, and performance measures. | According to Complex Adaptive System (CAS) theory, a trained facilitator can help overcome barriers to change and improvement.27
B. Targeted groups | Practice staff, patients, caregivers, and others who are the intended recipients or beneficiaries of PCMH. | —
C. Intervention source | Identifying who (which individuals or groups) originated the PCMH initiative and/or from which source the components of the initiative were derived. | —
D. Evidence strength and quality | Target group and other stakeholders' perceptions of the quality and validity of evidence supporting the belief that the PCMH will have the desired outcomes.8 | Standards and recommendations from the National Committee for Quality Assurance.
E. Relative advantage | Target group and other stakeholders' perception of the advantage of PCMH instead of other possible interventions or maintaining the status quo.7 | —
F. Feasibility (NEW) | Target group and other stakeholders' perception of the extent to which the PCMH can be successfully used or carried out within a given organization or setting. | —
G. Adaptability | Target group and stakeholders' perception of the degree to which PCMH strategies, techniques, and practices can be adapted to meet local needs. | —
H. Trialability | Target group and stakeholders' perception of the ability to test and refine components of the PCMH on a small scale. | —
I. Complexity | Target group and stakeholders' perception of the duration, scope, centrality, and intricacy, and number of steps required to implement the intervention. | Team-based care coordination with multiple organizations vs. a disease registry within a single practice.
J. Compatibility (NEW) | Target group and stakeholders' perception of the alignment of the meaning, values, and norms attached to PCMH with those held by members of the practice or organization. | —
K. Radicalness (NEW) | Target group and stakeholders' perception of the degree of difference between the change envisioned and the current state.9 | —
L. User control (NEW) | The degree to which the intervention relies on staff authority/skill to implement PCMH on its own vs. reliance on external consultants. | —
M. Location of intervention (NEW) | Components of the intervention conducted outside the clinic/office setting using external service providers and organizations. | Case-management, home visits.
N. Workflows (NEW) | Office tasks and workflows, including interdependences between them that will be intentionally redesigned or impacted by the PCMH transformation.7 | —
O. Task/process standardization (NEW) | Degree to which the PCMH seeks to standardize selected tasks and/or processes that require iterative consultation. | —
P. History (NEW) | Experiences of similar interventions within the setting and within the target population. | Patients' experience with a patient navigator prior to PCMH.

Note: PCMH = patient-centered medical home.

Table 11 Patient-Centered Medical Home Framework—Outer Setting

Construct | Description | Examples
A. External networks | Practice's involvement with networks and partnerships that support the transition to PCMH and are involved in similar efforts. | Improvement collaborative.
B. External pressure | Pressure emanating from outside the organization to implement a PCMH intervention. | Key peer or competing organizations have already implemented PCMH; there is competitive pressure to secure a better share of the market.
C. External policy and incentives/disincentives | Laws and regulations (governmental or other central entity), recommendations and guidelines, and payment schemes that affect the decision to adopt or abandon PCMH. | Payer provides incentives for National Committee for Quality Assurance PCMH certification.
D. Technological environment (NEW) | Technological trends and movements, and the availability of technological innovations that may affect the intervention and its context. | Health information exchanges.
E. Population needs and resources (NEW) | Prevalence of conditions and disease in the population served and the characteristics of the community that are determinants of health status. | Environmental quality, poverty, transportation, employment, health determinants.
F. Community resources (NEW) | Availability and access to service providers, aging resources, and multiple levels of community services and supports not directly a part of the PCMH. | —

Note: PCMH = patient-centered medical home.

Table 12 Patient-Centered Medical Home Framework—Inner Setting

Construct | Description | Examples
A. Structural characteristics | Social architecture; age; maturity; size; composition of the team, unit, organization, or system; and the patient panel served. | Staffing mix, clinician demographics, clinician training, employment status of physicians.
B. Team and network characteristics | Influence, breadth, depth, and role diversity of teams and networks engaged in implementation of the PCMH.11 | —
B1. Teams, networks, and communications | Nature and quality of teams and social networks; formal/informal communication and information exchange within practice setting, with patients and caregivers. | —
B2. Team and network self-organization | Capacity to arrange and organize for a defined (nonrandom) purpose without external pressure or mandate.
C. Culture | Norms, values, and beliefs within a team, unit, or practice that affect views of PCMH and its implementation. | —
D. Implementation climate | Capacity or reserve12 for change and the shared receptivity of involved individuals to the intervention. | —
D1. Tension for change | Degree to which stakeholders perceive the current situation as intolerable or needing change. | —
D2. Mandate | Whether compliance with the PCMH initiative is expected. | —
D3. Accountability | Whether entities are subject to tangible consequences for noncompliance. | —
D4. Relative priority | Individuals' shared perception of the importance of the PCMH implementation within the organization. | —
D5. Organizational incentives | Extrinsic incentives and rewards offered to adopt PCMH. | Shared savings, promotions, increased stature, or respect.
D6. Learning climate11 | Organization's willingness to promote trial and error, test new methods, and innovate. | Routine and structured quality improvement activities.
E. Readiness for implementation | Tangible and immediate indicators of organizational commitment to its decision to implement PCMH. | —
E1. Leadership commitment | Degree of commitment, involvement, and accountability of leaders and managers to patient-centered care and the PCMH initiative. | —
E2. Staff commitment (NEW) | Degree of commitment, involvement, and accountability of physicians, nurses, and other staff for patient-centered care and to the PCMH. | —
F. Access to information, training, education. | Ease of access to digestible, applicable information about PCMH. Resources dedicated to training and education available within the organization. | Online training tools, time given for training and education, funding for training.
G. IT and HIT resources (NEW) | Technological infrastructure in place to support electronic information management and the redesign of patient care. | —
G1. HIT systems | Electronic information management infrastructure and technologies available to clinicians to manage patient care, data, and communications. | Patient portals, disease registries, mobile applications.
G2. IT systems | Technological systems and capabilities to support PCMH. | Hardware, software, server space, bandwidth, interoperability, health information exchange.
G3. HIT/IT accessibility (NEW) | Features of the physical, technical, and spatial environment of the practice that determine the use, accessibility, and acceptability of technology in patient care.13 | —
H. Physical space and equipment (NEW) | Physical space and equipment dedicated for or impacted by the PCMH intervention.14 | —
I. Staff time (NEW) | Time dedicated to implement the PCMH intervention. | Time given to staff to attend trainings and learn PCMH techniques and strategies; time allowed for adjustment and adaptation.
J. Patient self-management infrastructure (NEW) | Training, counseling, and education available to patients [underlined: prior] to PCMH within the practice setting or affiliated organizations. | —
K. Continuity (NEW) | Information continuity (exchange of information) and relationship continuity, both with provider and patients/caregivers and across organizations. | —
L. Patient-centeredness (NEW) | Extent to which the practice knows and prioritizes patient goals, needs, and preferences, and has the resources and services to meet them. | Patient needs assessments, patient portals, mobile health applications.

Note: HIT = health information technology; IT = information technology; PCMH = patient-centered medical home.

Table 13 Patient-Centered Medical Home Framework—Characteristics of Individuals and Teams

Construct | Description | Examples
A. Knowledge and beliefs | Views regarding the PCMH, as well as familiarity with facts, truths, and principles related to the intervention. | —
B. Skills and competencies (NEW) | Degree of relevant subject matter expertise, skills, and competencies within the implementing team, unit, and organization. | —
C. Role (NEW) | Individual's or team's role and responsibility, and extent of multiple or shared roles. | —
D. Authority (NEW) | Perceived and actual degree of authority to make decisions and act autonomously.15 | —
E. Self-efficacy | Confidence in the capacity to execute the courses of action necessary to achieve PCMH goals. | Patient confidence in accessing and using a patient portal.
F. Collective efficacy (NEW) | Conviction of individuals and teams involved that the PCMH can be carried out in cooperation with others.16 | Individual team members desire to become a PCMH but nursing staff believe they will have to do all the work.
G. Stage of change | Phase an individual or team is in; characterizes progress toward skilled, enthusiastic, and sustained application of PCMH strategies. | —
H. Identification with organization | How individuals or teams perceive the organization, and their relationship and degree of attachment with the organization. | —
I. Socioeconomic demographics (NEW) | Characteristics related to the individual's socioeconomic status. | —
J. Patient needs and resources (NEW) | Patient priorities for health and health care, and the social and economic capital to address those priorities. | —
K. Caregiver needs and resources (NEW) | Caregiver priorities for health and health care, and the social and economic capital to address those priorities. | —
L. Other personal attributes | Other personal traits not captured elsewhere. | Tolerance of ambiguity, intellectual ability, motivation, values, competence, capacity, learning style.

Note: PCMH = patient-centered medical home.

Table 14 Patient-Centered Medical Home Framework—Process of Implementation

Construct | Description | Examples
A. Planning | Degree to which implementation steps or tasks are developed in advance and in response to various scenarios; the quality of those schemes or methods. | Contingency planning.
A1. Assessing (NEW) | Formal assessment of the problem or condition to be changed, including barriers and facilitators to change. | —
A2. Goal-setting | Written goals, objectives, benchmarks, and timelines for PCMH activities, and their feasibility and adequacy. | —
A3. Feedback | Procedures used to provide feedback to stakeholders and their adequacy. | —
B. Acquiring and allocating resources (NEW ) | Staff time, space, equipment, and other resources dedicated to implementing the PCMH intervention; the adequacy of those allocations. | —
C. Process ownership (NEW) | The diversity of practice roles involved in processes of implementation; authority and accountability for these activities. | —
D. Practice roles | Roles of individuals involved in the decision to adopt, execute, and facilitate PCMH. | —
D1. Organizational leaders (NEW) | Managers and others with the authority to dedicate resources and make decisions to adopt, maintain, or abandon the implementation. | —
D2. Opinion leaders | Individuals who influence (positively or negatively) the attitudes and beliefs of their colleagues.17,18 | Experts and peers.19
D3. Implementation leaders | Individuals formally appointed with responsibility for implementing an intervention. | Coordinator, project manager, team leader.
D4. Champions | Individuals who dedicate themselves to galvanizing and maintaining support for PCMH and overcoming indifference or resistance. | —
D5. External change agents | Individuals outside the practice who can facilitate or undermine decisions about PCMH adoption and implementation. | Individuals from health plans, other health care systems, consultants, and policymakers.
D6. Facilitator (NEW) | Formally appointed role that provides reflective, empathetic, and interactive counsel. | Experts who model and teach new skills and practices.16
D7. Frontline staff (NEW) | Administrative staff and providers (within and outside the organization) who will implement the PCMH or be impacted by it. | —
D8. Patients and other stakeholders (NEW) | Patients and other stakeholders impacted by the PCMH. | Family members, advocates, and social service providers.
E. Engaging | Processes involved in attracting and involving appropriate individuals in the implementation and use of the intervention.10 | Social marketing, various outreach activities.
E1. Engaging organizations, external context (NEW) | Developing and capitalizing on relationships with providers, leaders, and frontline staff in the implementing organizations, and with external providers, resources, funders. | —
F. Executing | Manner in which those involved carry out and accomplish the implementation according to plan; the role and authority to execute.15 | —
F1. Decisionmaking (NEW) | Frequency, duration, and timing of the activities involved in making decisions.11 The directionality of these activities.20 | Decisions directed from the top down vs. the bottom up.
F2. Staging and iteration (NEW) | Whether the implementation is carried out in incremental steps, refined iteratively, or implemented in its entirety within a specified period | —
F3. Facilitating and coaching | Use of experts to teach new processes, model best practices, and develop solutions; the structure, formality, and adequacy of these facilitative activities. | —
G. Reflecting and evaluating | Quantitative and qualitative feedback on the quality of the implementation process21^—^“reflexive monitoring” and the degree to which it is attained. | Project monitoring; systematic feedback processes.
G1. Measurement capability and data availability (NEW) | Availability of timely data. Capacity for monitoring, evaluation, and process improvement. Includes measurement differences; accountability for collection, documentation, and analysis. | —

Note: PCMH = patient-centered medical home.

Table 15 Patient-Centered Medical Home Framework—Measures of Implementation (new domain)

Construct | Description | Examples
A. Acceptability (NEW)2 | Degree to which PCMH goals, strategies, tactics, and specific activities are agreeable, palatable, or satisfactory. | —
B. Adoption/abandonment (NEW)2 | Intention, initial decision, or action to try to employ or cease PCMH. | —
C. Appropriateness (NEW)2 | Suitability of the PCMH intervention to the specific issues or problems to be addressed. | —
D. Intervention cost (NEW)2 | Costs of the PCMH interventions and costs associated with implementation, including investment, ongoing maintenance costs, and opportunity costs. | Training, staffing, IT updates.
E. Fidelity (NEW)2 | Degree to which PCMH was implemented as intended by those who developed and/or introduced it to the practice. | —
F. Reach (NEW) | Absolute number, proportion, and representativeness of targeted entities willing to participate in a given PCMH intervention.22 | —
F1. Reach within the population (NEW) | Number of patients within the targeted setting exposed to or participating in the PCMH intervention. | —
F2. Reach within the organization (NEW) | Absolute number, proportion, and representativeness of individuals and subcomponents within an organization exposed to or participating in the PCMH intervention.22 | Percentage of practices within a network that provide email consultations.
G. Penetration (NEW)2 | Depth of integration of a PCMH implementation within a service setting and its subsystems. | Among providers who have e-prescribing, the percentage of patients who receive e-prescriptions.
H. Replicability (NEW) | Degree to which the PCMH implementation process and outcomes can be reproduced beyond the adopting practice sites. | —
I. Sustainability (NEW)2 | Degree to which changes resulting from PCMH are maintained or institutionalized within a practice. | —
J. Evolvability (NEW) | Extent to which the change is capable of being sustained through adaptation and refinement. | —

Note: IT = information technology; PCMH = patient-centered medical home.

Table 16 Patient-Centered Medical Home Framework—Outcomes (new domain)

Construct | Description | Examples
A. Patient- and caregiver-centered outcomes (NEW) | Patient- and caregiver-defined goals and care consistent with patient and caregiver preferences. | Patient and caregiver would rather be seen by a physician than by a nurse practitioner.
B. Patient/caregiver experience (NEW) | Impact of PCMH on patient and caregiver experiences with care, including satisfaction with care and patient-provider interactions.21 | —
C. Provider experience (NEW) | Effect(s) of PCMH on a provider's burden of effort and quality of work life, communication, and interactions with patients and colleagues.21 | —
D. Process of care (NEW) | Key measurable processes of PCMH interventions.23,24 | —
D1. Patient-centered (NEW) | Extent to which PCMH engages patients and family in care decisions, provides resources for self-management, and is culturally and linguistically appropriate.23 | —
D2. Coordinated (NEW) | Extent to which practice tracks, follows up on, and manages tests, referrals, and care at other facilities; follows up with discharged patients; and ensures continuity of care.23 | —
D3. Comprehensive (NEW) | Extent to which the intervention satisfies all the health care needs of a patient, including prevention and specialty care.24 Includes access and ability to pay. | —
D4. Accessible (NEW) | Extent to which PCMH delivers routine/urgent care and clinical advice during and after business hours, provides electronic access.23 | —
D5. Quality (NEW) | Extent to which PCMH shows an ongoing commitment to high quality through the use of performance measurement, evidence-based strategies, etc.24 | —
D6. Safety (NEW) | Extent to which PCMH collects and uses safety data, and shares such data publicly as a marker of ongoing commitment to safety and quality.24 | —
E. Effectiveness (NEW)3 | Extent to which the intervention contributes to providing services to all who could benefit, without providing services to those who would not. | —
F. Timeliness (NEW)3 | Extent to which the intervention contributes to reducing wait times and delays, both for those who provide care and those who receive it. | —
G. Equitable (NEW) | Extent to which disparities in care are reduced or eradicated.1 | —
H. Clinical outcomes (NEW) | Result of a medical intervention as captured by changes in health status. | —
I. Health care utilization (NEW) | Changes in the frequency, type, timing, and duration of health care services due to PCMH. | —
J. Cost effects/impact (NEW) | Cost impact (summative or incremental) to the practice/organization resulting from PCMH changes. Fixed and variable costs; offsets of the cost of implementation. | —
K. Value (NEW) | Perceived worth, utility, and importance of PCMH outcomes to the practice, the providers, and patients. | —
L. Unintended consequences (NEW) | Emergent, interim, or longer term outcomes that were unanticipated and usually not desired. | Staff burnout from burden of balancing “day job” with PCMH activities.

Note: PCMH = patient-centered medical home.

## Organization of the Patient-Centered Medical Home Framework

Tables 10 through 16 show the PCMH Framework. The content is organized into seven domains and further subdivided into precise categories of constructs and subconstructs. The elements are summarized with their definitions in the first two columns of the tables; those elements labeled “new” were not part of the original Consolidated Framework for Implementation Research (CFIR).3 The PCMH Framework domains, adapted from CFIR, are—

- Intervention Characteristics: The characteristics and features of the intervention being implemented into a particular organization or organizations, including core components (the essential and indispensable elements of the intervention itself). These may be fixed or mutable attributes; they are considered and assessed prior to implementation and influence adoption decisions.
- Outer Setting: The economic, political, and social context within which an organization resides.
- Inner Setting: Tangible and intangible manifestations of characteristics of the organizations involved in the intervention, including structural characteristics, networks and communications, culture, climate, and readiness, which all interrelate and influence implementation.
- Characteristics of Individuals and Teams: The individuals (as carriers of cultural, organizational, professional, and individual mindsets, norms, interests, and affiliations) involved with the intervention and/or implementation process. Includes patients and caregivers.
- Process of Implementation: Refers here to the course of actions (e.g., planning, engaging, and reflecting) to achieve individual- and organizational-level use of the intervention as designed.
- Measures of Implementation: Refer to what Proctor et al.5 call “implementation outcomes”; they are intermediary outcomes that describe how well the implementation was carried out and prospects for sustainability.
- Outcomes: The results of the PCMH implementation, defined as the targets of the PCMH intervention.

Users of the framework may find it helpful to refine these subconstructs even further for specific research purposes. Researchers could use these frameworks to define and review the range of potentially relevant concepts and variables as they prepare an implementation study. Additionally, they may engage in prestudy to determine which constructs are likely to be most useful. During their research, they may refine their selection of constructs and their specifications of them in response to data that emerge from the field or in response to changes in the intervention process and context that take place during the life course of the intervention.

## Modifications in the Patient-Centered Medical Home Framework

The CFIR served as the foundation for the PCMH Framework. In addition, the PR and PCMH Frameworks were developed simultaneously, and therefore additions to one framework resulted in similar additions to the other when appropriate. All construct and subconstruct additions are noted in Table B in the Executive Summary and Table 25 in the Discussion. Below, we briefly list by domain the constructs added to the PCMH Framework as a result of the adaptation work (i.e., not present in the original CFIR or in the PR Framework). For definitions of these constructs, we direct the reader to the PCMH Framework tables, which begin with Table 10.

- Intervention Characteristics: Some models of PCMH rely extensively on vendors and consultants to carry out PCMH activities such as case management or outreach. Thus, the location of the intervention may be partially outside the practice setting. The practice's history with similar PCMH interventions was deemed a potentially important factor in seeking to engage in these activities and ease of implementation.
- Outer Setting: A new construct, population needs and resources, was added because these needs may influence the kinds of services and care innovations the practice may pursue.
- Inner Setting: Patient-centeredness was added to capture the degree to which the practice is aware of patient needs and seeks to addresses them. Patient self-management infrastructure represents the resources made available to patients in the PCMH. The construct human factor that was added in the PR Framework was renamed HIT/IT (health information technology/information technology) accessibility to better resonate with PCMH users.
- Characteristics of Individuals and Teams: The new construct socioeconomic demographics provides a place for users to capture important information on patient groups. Role, authority, and collective efficacy are elements important to teaming and collaboration.
- Process of Implementation: We expanded on the planning construct and added the subconstruct assessing to cover activities designed to identify needs and barriers. Acquiring and allocating resources is typically a part of the process of implementation. To practice roles, we added organizational leaders, frontline staff, facilitator, and patients and other stakeholders to better articulate the focus on patients. Under execution, we added decisionmaking.
- Measures of Implementation: This is a new domain. The PCMH Framework does not contain any new constructs in this domain in addition to those described in the PR Framework.
- Outcomes: This is a new domain. The PCMH Framework added a number of PCMH-specific outcomes that the interventions seek to achieve for patients, providers, and health care utilization. These outcomes include process of care (further subdivided by six subconstructs: patient-centered, coordinated, comprehensive, accessible, quality, and safety), patient/caregiver experience, clinical outcomes, and health care utilization. The Technical Expert Panel raised the issue of the high burden of PCMH implementation, which provided the rationale for adding provider experience.

## Graphic Representation of the Patient-Centered Medical Home Framework

Figure 4 is a graphic representation of the PCMH Framework. It shows the relationships of five of the domains to measures of implementation success and various PCMH outcomes. On the left side of the figure is an inner circle with four domains: Intervention Characteristics, Individual/Team Characteristics, Inner Setting, and Process of Implementation. Surrounding this inner circle is an outer ring named the Outer Setting that may influence these four domains. An arrow to the right of the inner and outer circles points to the Measures of Implementation, which influence Outcomes.

Figure 4 Framework for Implementation Research on Patient-Centered Medical Homes

Figure 4 is a graphic representing the relationship between the domains of the Patient Centered Medical Home Framework. On the left side of the graphic, four domains are shown as equal quadrants of a circle. Starting from the left top quadrant these domains are: intervention characteristics, individual/team characteristics, inner setting and process of implementation, and inner setting. This circle is surrounded by another circle that represents the outer setting domain. These two concentric circles feed into an arrow-shaped box to the right labeled Measures of Implementation. The Measures of Implementation box feeds into an arrow-shaped box on the far right of the figure labeled Outcomes.

## How To Use the Patient-Centered Medical Home Framework

The evolving nature of PCMH interventions and the heterogeneity of the settings in which the PCMH model may be applied are such that the details of implementation will vary from one setting to another. Therefore, the PCMH Framework does not prescribe a set of normative constructs that must be considered; rather, it provides a large set of potential constructs within major domains, from which investigators can choose those constructs relevant to their particular intervention and goals, questions, theory, or model guiding the research or evaluation.

The flowchart in Figure 5 presents step-by-step guidance on how this framework may be used. The flowchart presents a series of questions, and each set of questions is tied to a particular domain in the framework (Tables 10 through 16). As these questions are considered, the user should refer to the appropriate domain in the framework table to see which constructs are relevant. For example, Step 1 corresponds to the Intervention Characteristics domain; as users consider the various issues related to this domain, they should refer to the framework to choose those constructs relevant to them.

Figure 5 How to use the Patient-Centered Medical Home Framework

Abbreviations: PCMH = Patient-Centered Medical Home.

Figure 5 is a flowchart with seven steps that correspond to the seven domains in the Patient Centered Medical Home Framework. The seven steps are aligned vertically in boxes, starting with step 1 at the top of the figure and ending with step 7 at the bottom of the figure. Each step has an arrow pointing down to the next step. The first step in the flowchart is to define the intervention. The second step is to define the outer setting. The third step is to define the inner setting. The fourth step is to define the characteristics of the individuals and teams involved in the intervention. The fifth step is to define the process of implementation. The sixth step is to define the measures of implementation. The seventh and final step is to define the outcomes. The right-hand side of each step includes a series of questions for users to consider in completing the step.

As mentioned previously, the framework does not prescribe which constructs must be selected due to the diversity of research objectives and to variations between different PCMH interventions. The frameworks are designed to be a practical tool for research and evaluation, and it would be unfeasible to include all or even most of the constructs described. While following this step-by-step process of using the framework, we recommend that users of the framework select qualities, features, or characteristics that are closely tied to intervention outcomes and aligned to the goal, questions, theory, or model guiding the research or evaluation. Doing so will help the user prioritize the constructs, remain focused on the essential aims of the investigation, and keep the number of constructs to a manageable size.

## Content of the Patient-Centered Medical Home Framework

We present the PCMH Framework in Tables 10 through 16 with brief definitions of the constructs and subconstructs, and examples. Constructs labeled “new” are additions to the original CFIR.3 Based on Technical Expert Panel input, we added clarifying examples and comments for those constructs and subconstructs that were unclear or complex. Each construct or subconstruct is independent and should be applied as appropriate to the research questions and objectives.

## Applying the Patient-Centered Medical Home Framework: A Case Study

To illustrate how the PCMH Framework may be applied, we present below a brief case study based on Driscoll et al., “Process and outcomes of patient-centered medical care with Alaska Native people at Southcentral Foundation.”28

### Alaska Southcentral Foundation Case Study

The Southcentral Foundation (SCF) provides health care services to nearly 60,000 Alaska Native and American Indian people living in south-central Alaska, including Anchorage and 50 rural villages. SCF was formerly managed by the Indian Health Service. In 1997, SCF assumed responsibility for the primary care services at the Alaska Native Medical Center. Two years later the SCF began implementing key components of the PCMH model. The tailored model is based on several key characteristics of a PCMH. These are described below:

- Team-based care. Coordinated care is delivered by multidisciplinary teams rather than by individual clinicians. These teams include primary care physicians or physician assistants, nurses, certified medical assistants, and other clinicians. Over time, behavioral health consultants, nutritionists, and appointment schedulers were added.
- Empanelment. Patients are matched, either by self-selection or assignment, to an integrated and comprehensive care team. Patients schedule primary care appointments with their team members.
- Open access. To the extent possible, patients' barriers to access are mitigated through open scheduling, expanded office hours, and increased availability of electronic communication between patients and team members.

In the remainder of the case study, we will use the example of SCF to demonstrate how the PCMH Framework may be used to evaluate this intervention.

### Applying the Patient-Centered Medical Home Framework

Below, we walk through the how-to-use flowchart detailed in Figure 5. For illustrative purposes we have used a brief case study and examine this study at a high level. In real-world implementations, the level of detail will be significantly greater. For each step, we have selected a few constructs as examples.

#### Step 1 Define the Intervention

In this step, the user of the framework examines the first major domain in the PCMH Framework, Intervention Characteristics.

- What is the intervention designed to achieve?
  The goal of the PCMH intervention is to improve access to and coordination of care among patients served by SCF's primary care services.
- What are the features of the intervention?
  Here, the user considers the details of the various intervention components specified above, which have three main components: empanelment, open access, and team-based care. In this case, we address all three, but another option is to limit the focus to only one of these components. The user may consider evidence strength and quality as a potential construct to include (e.g., perceptions of the quality and validity of the three components selected among key stakeholders at SCF; whether there are existing standards and/or publications that can provide supporting evidence).
- Who is the intended target group?
  Relevant constructs that may be used include targeted groups and workflows. See Table 10.

#### Step 2 Define the Outer Setting

- What components of the environment will impact the implementation?
  These may include political context, social context (including Native American subcultures), economic context, and population needs and resources (e.g., the specific health needs, if any, of the local Alaskan population and how the PCMH intervention will ensure that these needs are well served). See Table 11.

#### Step 3 Define the Inner Setting

- What components of structure and process within the inner setting will impact the implementation?
  These may be networks and communications, culture, climate, readiness, and so on. Relevant constructs here include structural characteristics (e.g., how many physicians are employed by the SCF; in how many buildings services are provided) and provider culture (e.g., how staff will adapt to the concept of team-based care, which will include more frequent communication and coordination between individuals; how comfortable physicians are with increased communications and how the transitions can be made smoother). See Table 12.

#### Step 4 Define the Characteristics of the Individuals/Teams Involved

- What are the characteristics of individuals (or teams) that will help in making the PCMH intervention and/or implementation successful?
  Here, the user could examine patient needs and resources (e.g., whether patients are able to schedule appointments during various hours when they need to do so; whether they can make appointments online or by email). Other relevant constructs here include skills and competences (e.g., whether staff members have the skills needed to successfully form integrated and comprehensive care teams; whether staff members require training); role (who is responsible for which tasks under the new team-based care); and authority (which physicians have override authority if there are multiple physicians involved in care for a patient). See Table 13.

#### Step 5 Define the Processes Required To Achieve Desired Level of Use

- What are the implementation processes that are required to achieve individual- and organizational-level use of the intervention?
  Relevant constructs to consider may include planning (e.g., whether the PCMH intervention has clear milestones, timelines, and dedicated staff accountable for actions) and staff time (e.g., whether staff are given sufficient time to implement various changes, while not compromising the various functions they are currently responsible for). See Table 14. This step does not cover how completely an intervention was used; this concept is covered under the Measures of Implementation domain.

#### Step 6 Define Measures of Implementation

- What are the attributes of the implementation process that demonstrate it was carried out well and can be replicated, scaled, and sustained?
  Relevant constructs here may include acceptability (e.g., the degree to which stakeholders find SCF's PCMH implementation agreeable and satisfactory), intervention cost (e.g., the total cost of implementing the three components of PCMH, and whether this stays within a set budget), and reach within the organization (e.g., the number of units within SCF where empanelment is functioning as expected 6 months after completion of intervention). See Table 15.

#### Step 7 Define the Outcomes

- What are the specific measurable outcomes that will result from the intervention?
  Relevant constructs, representing outcomes, may include process of care (e.g., whether the SCF is able to provide care that satisfies relevant defining attributes of PCMH, such as being coordinated, accessible, and patient centered). The user is encouraged to revisit previous domains to ensure that the outcomes selected in this step are logically supported by the intervention. In particular, the user would tie these outcomes back to the goals of the intervention (improving access and coordination of care) listed under the first step. See Table 16.

[underlined: Note:] The constructs in the PCMH Framework, because they represent components of a complex system intervention, can be explored at multiple levels (i.e., at the individual, team, or organizational level). The number of levels and their definitions will vary based on the specific scenario. In Table 17, we show how a handful of constructs applicable to this case study are relevant across multiple organizational levels. For brevity, we show only three levels, but other levels may be relevant, depending on the scenario. For example, in some cases, a “unit” might be a level composed of groups of “teams.” However the levels may be defined, the important aspect is to ensure that users of the framework appreciate that each construct may (and in most cases should) be applied at various levels, and not just at one.

Table 17 Example of application of Patient-Centered Medical Home Framework constructs to diverse levels of analysis by organizational level

Construct | Individual | Team | Organization
Evidence strength and quality | ✓ | N/A | N/A
Population needs and resources | N/A | N/A | ✓
Culture | ✓ | ✓ | ✓
Process of care | ✓ | ✓ | ✓

Note: N/A = not added.