# Methods

Adaptations of the Consolidated Framework for Implementation Research (CFIR) to process redesign for efficiency and reduced cost (PR), patient-centered medical homes (PCMH), and care transitions were modified using the feedback obtained from a literature scan, consultation with the original CFIR developer and experts familiar with that work, and two Technical Expert Panels (TEPs) that examined the framework objectively during a series of calls. In this section, we briefly describe the four methods used for the adaptation and refinement: (1) a brief literature scan, (2) TEPs to inform the content and use of each of the three draft contextual frameworks, (3) TEPs to inform the usability of the PR and PCMH Frameworks, and (4) a self-assessment of the first-phase project.

The work was carried out in two discrete phases: phase 1 (January 2012 through June 2012) and phase 2 (September 2012 to September 2013). In phase 1, we developed the draft PR and PCMH Frameworks. In phase 2, we conducted a self-assessment of phase 1, refined the frameworks, and modified the process for the adaptation of the Care Transitions Framework. The project's timeframe did not allow for a TEP to assess the usability of the Care Transitions Framework.

Our framework adaptation process was iteratively built from a set of sequential activities, as depicted in Figure 1. Much of this adaptation process was developed during the project rather than a priori. The first activity, the literature scan, informed the initial draft of the adapted framework. This draft was subsequently revised using feedback from the TEPs and then finalized through the input of peer reviewers and public comments.

Figure 1 Contextual framework development

Note: TEP = Technical Expert Panel.

Figure 1 represents the process used to develop the contextual frameworks. The figure consists of eight boxes that represent the various tasks of adaptation; the boxes are arranged vertically and horizontally to indicate the sequence of activities. The top row consists of a box on the left labeled Literature Scan with an arrow pointing to a box on the right labeled Identify and Select TEPs. The second row consists of three boxes. The first box on the left is labeled Identify Relevant Frameworks and has an arrow pointing to a box labeled Develop Draft Frameworks, which has an arrow pointing to a box labeled TEPs Review of Framework. Below the second row is a third row, with one box labeled Revise Draft Frameworks. An arrow from this box points to a box on the fourth row labeled Peer Review Public Comment. This box points to a box labeled Final Revised Framework (Final Report) at the bottom of the figure.

Upon deliberation, we selected a set of recommendations that were feasible to complete within the timeframe of this project. These included the majority of suggestions made by the TEPs; only a few suggestions (such as moving the frameworks online) were not addressed. In addition, we used these recommendations as we developed the initial drafts of the Care Transitions Framework. Likewise, a number of the recommendations from the Care Transitions TEP influenced the content of the final PR and PCMH Frameworks.

## Literature Scan

The adaptation process for each of the intervention-specific frameworks began with a scan of the literature, which included MEDLINE™, the published and gray literature, and articles recommended by content experts at AHRQ. We focused on articles published after January 2005 so as to overlap but not duplicate the period covered by the CFIR (published in 2009). We sought to identify relevant topic-specific contextual and theoretical frameworks, theories, and models that had not been covered in the CFIR. Furthermore, we conducted the literature scan so as to ensure that the frameworks were comprehensive in scope and captured the unique attributes and considerations of the intervention itself.

We used 50 search terms for the PR and PCMH literature scan singly and in combination (e.g., patient care management, health care redesign, implementation theory), and we used 18 terms for care transitions (e.g., hospital, transitional care, ambulatory care). The complete set of single search terms is listed in Appendix A. Using a set of structured abstraction questions, we reviewed each selected article to identify intervention-relevant components (an input, output, process, or outcome) not already included in the original CFIR that we could add as new constructs or use to refine and augment existing ones. The number of articles the literature scan identified and we selected for review and the methods we used for abstraction are shown in Appendix A. The articles included in the literature scan are listed in Appendix B.

The investigative team used the results of the literature scans–the abstracted components from reviewed articles that could adapt or refine the CFIR–to develop the two primary components of each framework: a table listing domains and constructs, their definitions, and examples (for selected constructs) and a graphical representation of the framework components. Knowing the literature scan might overlook important literature, we relied on the AHRQ technical experts and TEP members throughout the development process to identify additional papers not identified in the initial review.

## Content and Use Technical Expert Panels

We recruited three TEPs, one each for PR (8 members), PCMH (7 members), and Care Transitions (11 members), to assess the content and use of the draft contextual frameworks. Individuals recruited to each TEP had extensive experience in the intervention in one of the following three capacities: research and evaluation, management and practice, or general implementation research. The goal of TEP recruitment was to include individuals with diverse professional perspectives and ensure representation in these three capacity areas. For the Care Transitions TEP, we also sought to include key organizations involved in care transitions interventions and initiatives—Re-Engineered Discharge (RED), State Action on Avoidable Rehospitalization (STAAR), and the Community-Based Care Transitions Program (CCTP). These subject-matter experts were identified through the literature scan, AHRQ project officers, and the experts themselves, who recommended colleagues to the team. For each topic, we held two rounds of TEP conference calls, with each group call lasting 2 hours. We held 1-hour individual calls with experts who were not available for the group calls.

A set of structured questions guided each TEP discussion, with a focus on examining the relevance and suitability of the framework graphics, constructs, definitions, examples, and case studies. We used detailed notes from each call to revise the framework materials. Input from the PCMH TEP was used to refine the PR Framework and vice versa. Working in tandem, the TEPs identified issues that might not have been raised by each TEP on its own and produced greater depth and breadth of input for the adaptation process. The Care Transitions TEP completed their work after the PR and PCMH TEPs, but a number of their recommendations influenced the content of the PR and PCMH Frameworks.

## Usability Technical Expert Panels

After framework development, we convened two TEPS to assess the usability of the PR and PCMH Frameworks. TEP members represented researchers, health care executives, and providers who would be potential users of the frameworks. We used criteria for framework utility (familiarity, resonance, parsimony, coherence, and differentiation)4 to guide our discussions. Further details are found in Appendix C.

## Self-Assessment

During the second phase of the project, we conducted a self-assessment early on to apply lessons learned to the Care Transitions TEP and to gather final recommendations for the PR and PCMH Frameworks. The self-assessment included a self-assessment questionnaire we emailed to the initial TEP members to gather feedback on the procedures and materials we had used during their calls. In addition, a member of the investigative team not involved in the first phase reviewed the procedures and materials for clarity and effectiveness in meeting TEP aims.

## Peer and Public Review

Experts in the PR, PCMH, and Care Transitions fields as well as individuals representing stakeholder and user communities were invited to provide external peer review of this report, and AHRQ and an associate editor also provided comments. The draft report was posted to the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revised the text as appropriate, and documented the items in a disposition-of-comments report.