# Introduction

## Background

In January 2012, the Agency for Healthcare Research and Quality (AHRQ) contracted with the RTI International–University of North Carolina at Chapel Hill Evidence-based Practice Center to develop integrative contextual frameworks that would guide implementation researchers and evaluators of two types of complex systems of intervention: process redesign for improved efficiency and reduced cost (PR) and patient-centered medical homes (PCMH). Under a follow-on contract initiated in September 2012, a similar effort was launched for care transitions between hospital and ambulatory care settings. These three interventions are supported by AHRQ in its research portfolio as an investment in strategies that hold the potential to improve health care and delivery. Thus, the context of implementation, the processes underlying these interventions; and the implications for sustainability and replicability deserve as much attention as the outcomes of these interventions. However, the lack of common understanding or awareness of context among researchers and evaluators of these interventions poses a significant barrier to evidence building. These integrated frameworks seek to address this barrier and provide a common point of reference to guide future work.

The focus on complex system interventions is part of AHRQ's ongoing effort to bring new and useful perspectives to bear on how researchers conceptualize health care organization and delivery. In its report Crossing the Quality Chasm,1 the Institute of Medicine put forth a case for incorporating the perspectives of complexity science, specifically Complex Adaptive Systems, in the design of health care interventions. The care systems in which PR, PCMH, and care transitions seek to intervene bear many of the defining attributes and features of a Complex Adaptive System. These systems are “complex,” meaning they are diverse both in their constituent parts and general form. They are capable of changing in response to feedback and experience and are thus “adaptive.” Their structure aligns to that of a “system,” which is a set of interdependent entities enmeshed and embedded within one another.

Context is a critical factor within this highly adaptive and dynamic environment because all potential confounding variables cannot be controlled through randomization and stratification. Even clinical interventions, tested under highly controlled settings, may eventually be scaled to settings and populations very unlike those in which they were originally tested. Therefore, the key question for any kind of intervention applied to a Complex Adaptive System is not only, “Does it work?” but under what conditions and for which populations these interventions are more or less effective. Implicit in these questions is the notion that the context will change the intervention and vice versa. However, no common definition of context exists. Shekelle et al., speaking about patient safety practices, note: “There is no standard definition of ‘context.’ It may include detailed information about processes of implementation, as well as barriers and facilitators related to the organizational and policy environment in which a patient safety practice is implemented.”2, ^p.9^

We identified the Consolidated Framework for Implementation Research (CFIR)3 as a practical model for furthering the definition and conception of context for complex systems interventions. As the goal of our effort was to create an integrated framework, starting with a framework that had already reviewed and synthesized existing frameworks was an obvious choice. At the time, to our knowledge, the CFIR was the only integrated framework of its kind. The CFIR addressed the need of researchers and evaluators to assess the effectiveness of implementation within a specific context, and to not only maximize the benefit within that context but also promote dissemination to other contexts. Numerous theories of implementation and context existed in the literature but had differing and overlapping terminologies and constructs. The CFIR synthesizes these various terminologies, definitions, and constructs into a consolidated framework and a common taxonomy for implementation research on health service delivery. Drawing on 19 different theories, the CFIR consists of five domains that describe the internal and external context of implementation: Intervention Characteristics, Outer Setting, Inner Setting, Characteristics of the Individuals, and Process. The CFIR does not posit any particular set of hypotheses or causal pathways and does not confine itself to any one theory.3

Table 1 presents these domains categorized into more discrete elements (constructs). These domains interact with one another in a multidirectional fashion (the outer setting influences the inner setting and vice versa) and include multilevel influences (e.g., individual, organizational). The focus of the framework is on the interaction between context and processes, so it does not posit a causal pathway to specific outcomes.

Table 1 Consolidated Framework for Implementation Research (CFIR) domains and constructs

Domain | Construct
Intervention Characteristics | Intervention Source Evidence Strength and Quality Relative Advantage Adaptability Trialability Complexity Design Quality and Packaging Cost
Outer Setting | Patient Needs and Resources Cosmopolitanism Peer Pressure External Policy and Incentives
Inner Setting | Structural Characteristics Networks and Communications Culture Implementation Climate Readiness for Implementation
Characteristics of Individuals | Knowledge and Beliefs About the Intervention Self-Efficacy Individual Stage of Change Individual Identification With Organization Other Personal Attributes
Process | Planning Engaging Executing Reflecting and Evaluating

Source: Damschroder LJ, Aron DC, Keith RE, et al. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implement Sci. 2009;4(1):50. [pmid: 19664226]. .

The contextual frameworks described here are comprehensive, heuristic tools designed for researchers for the purpose of generating novel and compelling questions, as well as to glean fresh insights for research and evaluation design. Investigators can use the contextual frameworks to examine in depth the conditions under which implementation occurs and the multitude of factors (and the complex web of relationships among them) that determine whether the intended outcomes are achieved. In short, these contextual frameworks bring to the fore how, why, where, and for whom an intervention succeeds or fails. Equally important, these contextual frameworks offer a general taxonomy and conceptualization of key implementation constructs. Used as a sort of universal guide by investigators engaged in similar fields of study, these contextual frameworks could enhance the comparability of these studies and the synthesis of their findings. Intervention designers, implementers, and decisionmakers will gain a greater understanding of the generalizability and replicability of specific interventions.

The frameworks, due to the breadth and relevance of the constructs included, should acquaint the researcher or the implementing organization with the large range of contextual variables that are possible and important to consider in a study or evaluation. The frameworks can be used by investigative teams planning multisite studies or funders supporting a portfolio of grants to deliberate on the core constructs needed for cross-site analysis. However, we recognize that the sheer number of constructs can be overwhelming and, at the suggestion of our Technical Expert Panels (TEPs), we added a general roadmap to guide in the selection of a parsimonious set of constructs. As every study is unique, there is no simple recipe for construct selection. The decision to include or leave out specific constructs should be rooted in the context of the study itself.

## Scope

Our task was to build upon the CFIR, by examining its suitability and adapting it as necessary to the unique research and evaluation requirements of PR, PCMH, and care transitions through literature scans and a series of intervention-specific TEPs. We determined at the outset that some degree of adaptation would be required because the CFIR, as a general model of implementation within bounded organizational settings, might not speak to the unique and distinct attributes of complex system interventions. For each intervention, we used TEP input about enhancing usability and relevance to modify the CFIR (e.g., definitions, terms, organization, and structure). We did not systematically assess the validity or weight of evidence of each construct or identify their measures; although this remains an important next step in the development of the frameworks. As a research and evaluation tool the frameworks remain limited to a taxonomy of domains and their related constructs and subconstructs, and do not address study design, the data collection methods, or statistical analyses.

Users of the resulting adapted frameworks—the PR Framework, PCMH Framework, and Care Transitions Framework—should view them as works in progress intended to evolve and adapt to the context in which they are applied.

## Organization of the Report

The remainder of the report is composed of six chapters. The first of these is a general Methods chapter, which describes the general procedures for framework adaptation. The three chapters that follow present the PR, PCMH, and Care Transitions Frameworks, respectively. These chapters are organized similarly and present: (1) a brief overview of the intervention topic; (2) a brief summary of framework modifications; (3) the contextual framework itself, represented in a conceptual graphic and detailed tables; (4) guidance for using the contextual framework; and (5) a case study application of the contextual framework. In the final two chapters, the Discussion highlights the cross-cutting conceptual and methodological issues the TEPs considered during the adaptation process, and the Conclusion presents recommendations for continued framework adaptation and refinement.

We suggest readers direct their attention to the framework closest to their interests. The chapters containing the frameworks are stand-alone documents, and the first two sections are nearly identical across the three frameworks. The content of the frameworks, though they have been tailored to the interventions, is also quite similar and the differences may not be readily apparent. A list of the differences is presented in Table B in the Executive Summary and Table 25 in the Discussion chapter. The frameworks are comprehensive but not exhaustive, and users should apply them in the manner that is most practical to their needs.