# Glossary

Term: Definition
Adoption: Adoption is the intention, initial decision, or action to use the intervention. Adoption helps prepare for implementation.
Constructs: Constructs are operational definitions of theoretical concepts. Constructs may involve different meanings or measured values when applied to different practice roles.
Context: Context involves the interrelations and interactions between constructs that condition the individual and organizational use of the intervention as designed.
Domains: Domains are groupings of related constructs. Frameworks often include multiple domains.
Framework: A framework systematically identifies and organizes potential constructs and relationships to provide a conceptual tool for integrating the elements of the intervention; the environment impacting the intervention; the individuals/teams involved in the intervention; and the structures, processes, and outcomes of the intervention.
Implementation: Implementation involves deliberately initiated processes to achieve use of the intervention as designed or deliberately initiated PR to guide system-wide changes of complex sociotechnical systems.
Intervention: An intervention is a specific, discrete activity, action, or technique intended to achieve a desired health or health care outcome. These may be implemented singly, as combinations or bundles, or as a strategy. A strategy later encompasses a set of practices, techniques, or interventions sharing an underlying logic or approach for achieving the desired outcome.
PCMH: “The patient-centered medical home (PCMH) is a promising primary care approach that emphasizes patient-centered, comprehensive, coordinated, accessible care, with a systematic focus on quality and safety. The goal of these models is to improve quality, cost, and patient and provider experience.”^e^
  e Source: Agency for Healthcare Research and Quality. Expanding the Toolbox: Methods To Study and Refine Patient-Centered Medical Home Models. PCMH Research Methods Series. AHRQ Publication No. 13-0012-EF. 2013. .
PR: PR examines interactions among components of complex sociotechnical systems (e.g., health care delivery systems) and provides resources and tools to guide system-wide changes that improve care value and its safety, effectiveness, patient-centeredness, timeliness, efficiency, and equity of care.^f^
  f Source: Agency for Healthcare Research and Quality. System Design: AHRQ Resources. www.ahrq.gov/professionals/quality-patient-safety/patient-safety-resources/resources/systemdesign.html#process. 2013. June 14, 2013. .
Practice Roles: Practice roles include the individuals within and outside the practice, network, or organizations involved in the decision to adopt, execute, and facilitate the intervention. Examples of practice roles include external change agents, organizational leaders, and frontline staff.
Process: Process involves a course of actions (e.g., planning, engaging, and reflecting) to achieve individual- and organizational-level use of the intervention as designed.
Transitional Care: “Transitional care is defined as a set of actions designed to ensure the coordination and continuity of health care as patients transfer between different locations or different levels of care within the same location. Representative locations include (but are not limited to) hospitals, sub-acute and post-acute nursing facilities, the patient's home, primary and specialty care offices, and long-term care facilities.”^g^
  g Source: Coleman EA, Boult CE, on behalf of the American Geriatrics Society Health Care Systems Committee. Improving the quality of transitional care for persons with complex care needs. J Am Geriatr Soc. 2003;51(4):556-7. [pmid: 12657079]. .