# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Shannon Bolon, M.D., M.P.H.
  Chief, Primary Care Medical Education Branch, Division of Medicine and Dentistry, Bureau of Health Professions
  Health Resources and Services Administration
  Rockville, MD
- Signe Flottorp
  Senior Researcher
  Norwegian Knowledge Center for Health Sciences
  Oslo, Norway
- Caroline Ryan, M.A.
  Aging Services Program Specialist
  Office of Program Innovation and Demonstration
  U.S. Administration on Aging
  Washington, DC
- Lucy Savitz, Ph.D., M.B.A.
  Director of Research and Education, Institute for Health Care Delivery Research
  Intermountain Healthcare
  Research Professor, Clinical Epidemiology
  Director, CCTS Patient Centered Research Methods Core
  University of Utah
  Salt Lake City, UT
- Paul Shekelle, M.D., M.P.H., Ph.D.
  Director, Southern California Evidence-Based Practice Center
  RAND Corporation
  Santa Monica, CA