# Technical Expert Panels

In developing the contextual frameworks, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant report. Therefore, in the end, methodologic approaches, the content of the frameworks and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The lists of Technical Experts who participated in developing this report follow.

## Patient-Centered Medical Home Technical Expert Panel

- Robert Berenson, M.D.
  Institute Fellow, Urban Institute
  Washington, DC
- Stephan Fihn, M.D., M.P.H., FACP
  Director, Office of Analytics and Business Intelligence
  Department of Veterans Affairs
  Professor, Departments of Medicine and of Health Services
  Head, Division of General Internal Medicine
  University of Washington
  Seattle, WA
- Charles Homer, M.D., M.P.H.
  President and CEO, National Initiative for Children's Healthcare Quality
  Boston, MA
- Brian Mittman, Ph.D.
  Senior Advisor, U.S. Department of Veterans Affairs Center for Implementation Practice and Research Support
  Senior Scientist, Kaiser Permanente Southern California Department of Research and Evaluation
  Los Angeles, CA
- Michael Parchman, M.D., M.P.H.
  Director, MacColl Center
  Group Health Research Institute
  Seattle, WA
- Debra Peikes, Ph.D.
  Senior Researcher, Mathematica Policy Research
  Princeton, NJ

## Process Redesign Technical Expert Panel

- Laura Damschroder, M.P.H., M.S., B.S.
  Co-Implementation Research Coordinator, Diabetes QUERI
  U.S. Department of Veterans Affairs
  Ann Arbor, MI
- Kenneth M. Davis, M.D., M.Sc.H.P.&M.
  Chief Medical Officer, San Antonio Methodist Health System
  San Antonio, TX
- Kelly Devers, Ph.D.
  Senior Fellow, Health Policy Center, Urban Institute
  Washington, DC
- Bradley Doebbeling, M.D., M.Sc.
  Chair, Department of Biohealth Informatics
  Professor of Informatics, Medicine and Biomedical Engineering
  Indiana University School of Informatics & Computing, IUPUI
  Indianapolis, IN
- Richard Holden, Ph.D.
  Assistant Professor, Department of Medicine, Department of Biomedical Informatics
  Vanderbilt University School of Medicine
  Nashville, TN
- Cerry Klein, Ph.D.
  Professor, Industrial and Manufacturing Systems Engineering
  University of Missouri
  Columbia, MO
- Brian Mittman, Ph.D.
  Senior Advisor, U.S. Department of Veterans Affairs Center for Implementation Practice and Research Support
  Senior Scientist, Kaiser Permanente Southern California Department of Research and Evaluation
  Los Angeles, CA
- John Ovretveit, Ph.D.
  Director of Research, Professor of Health Improvement, Implementation and Evaluation, Medical Management Centre, The Karolinska Institutet
  Stockholm, Sweden

## Care Transitions Technical Expert Panel

- Mary Blumberg, M.S., R.D.
  Atlanta Regional Commission
  Atlanta, GA
- Amy Boutwell, M.D., M.P.P.
  President, Collaborative Healthcare Strategies
  Lexington, MA
- Jane Brock, M.D., M.S.P.H.
  Chief Medical Officer, Colorado Foundation for Medical Care
  Englewood, CO
- David Dietz, M.S.W., M.H.S.A.
  Senior Public Health Analyst, Hospital State Division, Office of Rural Health Policy
  Health Resources and Services Administration
  Rockville, MD
- Brian Jack, M.D.
  Professor and Chair, Department of Family Medicine
  Boston University School of Medicine
  Boston, MA
- Margaret (Peggy) Leonard, M.S., R.N.-B.C., FNP
  Senior Vice President, Clinical Services
  Hudson Health Plan
  Tarrytown, NY
- Kathleen (Kathy) McCauley, Ph.D., R.N., A.C.N.S.-B.C., FAAN, FAHA
  Associate Dean for Academic Programs
  University of Pennsylvania School of Nursing
  Philadelphia, PA
- Sumant Ranji, M.D.
  Associate Professor of Clinical Medicine
  Associate Program Director, Internal Medicine Residency Program
  University of California, San Francisco
  San Francisco, CA
- Anne E. Sales, Ph.D., R.N.
  Research Scientist, Center for Clinical Management Research, VA Ann Arbor Healthcare System
  Professor, University of Michigan School of Nursing
  Ann Arbor, MI
- Juliana Tiongson, M.P.H.
  Social Science Research Analyst
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Mark Williams, M.D.
  Professor & Director, Center for Health Services Research
  University of Kentucky
  Lexington, KY

## Patient-Centered Medical Home Usability Technical Expert Panel

- Melinda Abrams, M.S.
  Vice President, Patient Centered Coordinated Care Program
  Commonwealth Fund
  New York, NY
- Janice L. Genevro, Ph.D..
  Lead, Improving Primary Care Initiative
  Center for Primary Care, Prevention, & Clinical Partnerships
  Agency for Healthcare Research & Quality
  Rockville, MD
- Marci Nielsen, Ph.D., M.P.H.
  Chief Executive Officer
  Patient Centered Primary Care Collaborative
  Washington, DC
- Claire Tanner, Ph.D.
  Program Director, Center for Data Management and Translational Research
  Michigan Public Health Institute
  Okemos, MI
- Suzanne Wensky, Ph.D.
  Social Science Research Analyst
  Division of Research on Payment and Accountability
  Research and Rapid-Cycle Evaluation Group
  Center for Medicare and Medicaid Innovation
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Elizabeth M. Yano, Ph.D., M.S.P.H.
  Director, VA HSR&D Center for the Study of Healthcare Innovation, Implementation & Policy
  VA Greater Los Angeles Healthcare System
  Sepulveda, CA

## Process Redesign Usability Technical Expert Panel

- Ruth Boaden, Ph.D.
  Professor of Service Operations Management, Manchester Business School
  Director, National Institute for Health Research Collaboration for Leadership in Applied Health Research and Care (CLAHRC) Greater Manchester
  Manchester, United Kingdom
- Pascale Carayon, Ph.D.
  Procter & Gamble Bascom Professor in Total Quality, Department of Industrial and Systems Engineering
  Director, Center for Quality and Productivity Improvement
  University of Wisconsin
  Madison, WI
- Craig Froehle, M.B.A., Ph.D.
  Associate Professor, Operations Management
  Linder College of Business
  University of Cincinnati
  Cincinnati, OH
- Joanna Omi, M.P.H.
  Senior Vice President, Organizational Innovation and Effectiveness
  New York City Health and Hospitals Corporation
  New York, NY
- Lucy Savitz, Ph.D., M.B.A.
  Director of Research and Education, Institute for Health Care Delivery Research
  Intermountain Healthcare
  Research Professor, Clinical Epidemiology
  Director, CCTS Patient Centered Research Methods Core
  University of Utah
  Salt Lake City, UT