# Senior Advisors

- Tim Carey, M.D., M.P.H.
  Kenan Professor of Medicine
  Director, Cecil G. Sheps Center for Health Services Research
  University of North Carolina at Chapel Hill
  Chapel Hill, NC
- Sam Cykert, M.D.
  Professor of Medicine
  Associate Director for Medical Education, NC Area Health Education Centers
  Clinical Director, North Carolina Regional Extension Center for Health Information Technology
  University of North Carolina at Chapel Hill
  Chapel Hill, NC
- Timothy Daaleman, D.O., M.P.H.
  Professor and Vice Chair of Family Medicine
  Research Fellow in the Program on Aging, Disability, and Long-Term Care, Cecil G. Sheps Center for Health Services Research
  University of North Carolina at Chapel Hill
  Chapel Hill, NC
- Meera Viswanathan, Ph.D.
  Director, RTI-UNC Evidence-based Practice Center IV
  RTI International
  Research Triangle Park, NC
- Brian Weiner, Ph.D.
  Professor, Department of Health Policy and Management, Gillings School of Global Public Health
  Director, Program on Health Care Organization, Cecil G. Sheps Center for Health Services Research
  University of North Carolina at Chapel Hill
  Chapel Hill, NC