# Executive Summary

## Background

In January 2012, the RTI International (RTI)–University of North Carolina at Chapel Hill Evidence-based Practice Center initiated a project to develop integrative contextual frameworks that would guide researchers and evaluators of two types of complex systems of intervention: process redesign for improved efficiency and reduced costs (PR), and patient-centered medical homes (PCMH). Under a follow-on contract initiated in September 2012, a similar effort was launched for care transitions^a^ between hospital and ambulatory care settings (care transitions). The Agency for Healthcare Research and Quality (AHRQ) supports these three interventions in its research portfolio as investments in strategies that hold the potential to improve health care and delivery. Thus, the context of implementation; the processes underlying these interventions; and the implications for sustainability, replicability, and generalizability deserve as much attention as the outcomes of these interventions. However, the lack of common understanding or awareness of context among researchers and evaluators of these interventions poses a significant barrier to evidence building. The integrated frameworks are intended to address this barrier and provide a common point of reference to guide future work.

a In this document, we use the term “care transitions” to refer to a broad class of interventions and initiatives designed to enhance the patient's transition from a hospital to an ambulatory care setting, including but not limited to the Care Transitions Program^©^ developed by Dr. Eric Coleman (www.caretransitions.org/).

A technical expert in implementation research advising RTI during the planning stages of this work identified the Consolidated Framework for Implementation Research (CFIR)1 as a practical model amenable to complex systems intervention research. Numerous theories of implementation and context existed in the literature but had differing and overlapping terminologies and constructs. The CFIR synthesizes these various terminologies, definitions, and constructs into a consolidated framework and a common taxonomy for implementation research on health service delivery. It draws from a wide range of disciplines and does not confine itself to any one theory.1 The CFIR addressed the needs of researchers and evaluators to assess and maximize the effectiveness of implementation within a specific context, and promote dissemination to other contexts.

As the goal of this effort was to create an integrated framework, starting with a framework that already resulted from review and synthesis of existing frameworks was an obvious choice. Moreover, the broad range of constructs in the CFIR encompassed most of the contextual dimensions relevant to PR, PCMH, and care transitions. We determined at the outset that some degree of adaptation would be required because the CFIR, as a general model of implementation within bounded organizational settings, might not speak to some of the unique and distinct attributes of complex system interventions.

The CFIR consists of 5 domains and 26 more discrete elements (constructs) that describe the internal and external context of implementation. The domains are Intervention Characteristics, Outer Setting, Inner Setting, Characteristics of Individuals, and Process. Table A presents these domains categorized into constructs. The domains interact with one another in a multidirectional fashion (the outer setting influences the inner setting and vice versa) and include multilevel influences (e.g., individual, organizational). The focus of the framework is on the interaction between context and processes, so it does not posit a causal pathway to specific outcomes.

Table A Consolidated Framework for Implementation Research (CFIR) domains and constructs

Domain | Construct
Intervention Characteristics | Intervention Source Evidence Strength and Quality Relative Advantage Adaptability Trialability Complexity Design Quality and Packaging Cost
Outer Setting | Patient Needs and Resources Cosmopolitanism Peer Pressure External Policy and Incentives
Inner Setting | Structural Characteristics Networks and Communications Culture Implementation Climate Readiness for Implementation
Characteristics of Individuals | Knowledge and Beliefs About the Intervention Self-Efficacy Individual Stage of Change Individual Identification With Organization Other Personal Attributes
Process | Planning Engaging Executing Reflecting and Evaluating

Source: Damschroder LJ, Aron DC, Keith RE, et al. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implement Sci. 2009;4(1):50. [pmid: 19664226]. .

Investigators can use the PR, PCMH, and Care Transitions Frameworks to examine in depth the conditions under which implementation occurs. The frameworks bring to the fore how, why, where, and for whom an intervention succeeds or fails. Equally important, these frameworks offer a general taxonomy and conceptualization of key implementation constructs. Investigators engaged in similar fields of study could use them as a sort of universal guide to enhance the comparability of studies and the synthesis of findings. The benefit to intervention designers, implementers, and decisionmakers is a greater understanding of the generalizability and replicability of specific interventions.

The frameworks, due to the breadth and relevance of the constructs included, should acquaint the researcher or the implementing organization with the large range of contextual variables that are possible and important to consider in a study or evaluation. The frameworks can be used by investigative teams planning multisite studies or funders supporting a portfolio of grants to deliberate on the core constructs needed for cross-site analysis. However, we recognize that the sheer number of constructs can be overwhelming; at the suggestion of the Technical Expert Panels (TEPs), we added a general roadmap to guide in the selection of a parsimonious set of constructs. As every study is unique, there is no simple recipe for construct selection. The decision to include or leave out specific constructs should be rooted in the context of the study itself.

## Scope

Our task was to build upon the CFIR by examining its suitability and adapting it as necessary to the unique research and evaluation requirements of PR, PCMH, and care transitions through literature scans and a series of intervention-specific TEPs. We assessed the suitability and fit of each CFIR component to the research and evaluation needs of each of the three interventions. Using the input of the TEP members and AHRQ technical experts, and a brief literature update, we modified the elements of the CFIR (e.g., definitions, terms, organization, and structure) to enhance usability and relevance.

We did not systematically assess the validity or weight of evidence of each construct or identify their measures; these remain important next steps in the development of the frameworks. As a research and evaluation tool, the frameworks remain limited to a taxonomy of domains and their related constructs and subconstructs; they do not address study design, data collection methods, or statistical analyses.

## Methods

In this section, we briefly describe the four methods used for the adaptation and refinement of the CFIR: (1) a brief literature scan, (2) TEPs to inform the content and use of each of the three draft contextual frameworks, (3) TEPs to inform the usability of modified frameworks, and (4) a self-assessment of the first-phase project.

The work was carried out in two discrete phases: phase 1 (January 2012 through June 2012) and phase 2 (September 2012 to September 2013). In phase 1, we developed the draft PR and PCMH Frameworks. In phase 2, we conducted a self-assessment of phase 1, refined the frameworks, and modified the process for the adaptation of the Care Transitions Framework. The project's timeframe did not allow for a TEP to assess the usability of the Care Transitions Framework.

Our framework adaptation process was iteratively built from a set of sequential activities, as depicted in Figure A. The first activity, the literature scan, informed the initial draft of the adapted framework. This draft was subsequently revised using the feedback from the TEPs and then finalized through the input of Peer Reviewers and public comments.

Figure A Contextual framework development

Note: TEP = Technical Expert Panel.

Figure ES-1 represents the process used to develop the contextual frameworks. The figure consists of eight boxes that represent the various tasks of adaptation; the boxes are arranged vertically and horizontally to indicate the sequence of activities. The top row consists of a box on the left labeled Literature Scan with an arrow pointing to a box on the right labeled Identify and Select TEPs. The second row consists of three boxes. The first box on the left is labeled Identify Relevant Frameworks and has an arrow pointing to a box labeled Develop Draft Framework, which has an arrow pointing to a box labeled TEPs Review of Framework. Below the second row is a third row, with one box labeled Revise Draft Frameworks. An arrow from this box points to a box on the fourth row labeled Peer Review Public Comment. This box points to a box labeled Final Revised Framework (Final Report) at the bottom of the figure.

### Literature Scan

The three literature scans began with a search of articles in MEDLINE™, the published and gray literature, and articles recommended by content experts at AHRQ. We chose to limit our search to articles published after January 2005 so as to overlap but not duplicate the review conducted for the CFIR (published in 2009). Our goal was to identify relevant topic-specific contextual and theoretical frameworks. We used 50 search terms for the PR and PCMH literature scan singly and in combination (e.g., patient care management, health care redesign, implementation theory), and we used 18 terms for care transitions (e.g., hospital, transitional care, ambulatory care). A general set of questions guided the abstraction of the included articles. The investigative team used the results of the literature scans to develop the two primary components of each framework: a graphical representation and a table listing domains and constructs, their definitions, and examples (for selected constructs). The questions for the care transitions abstraction were tailored to identify content not already captured in the contextual frameworks.

### Technical Expert Panels

We convened two TEPs in 2012, one each for PR (8 members) and PCMH (7 members). Individuals recruited to each TEP included researchers with extensive experience in one or more of the following three areas relevant to the intervention: research and evaluation, management and practice, and general implementation research. A similar protocol was followed to recruit the 11-member Care Transitions TEP, convened in 2013. We sought to include individuals with a range of professional perspectives. These subject matter experts were identified through the literature scan, AHRQ project officers, and the experts themselves, who recommended colleagues to the team. For each topic, we held two rounds of TEP conference calls, with each group call lasting 2 hours. We held 1-hour individual calls with experts who were not available for the group calls. A set of structured questions guided each TEP discussion to examine the relevance and suitability of the framework graphics, constructs, definitions, examples, and case studies. We used detailed notes from each call to revise the framework materials.

Two additional TEPs evaluated the usability of the PR and PCMH Frameworks using a similar approach. Because the focus was on the usability of the framework, the members of these TEPS differed from those in the first round. Besides researchers, we recruited health care executives and providers, who would be potential users of the frameworks. The PR usability TEP had five members and the PCMH usability TEP had six members.

### Self-Assessment

In addition to receiving feedback from the usability TEPs, we conducted a self-assessment of the initial phase of the project prior to developing the Care Transitions Framework. The purpose of the self-assessment was twofold: to further the development of the PR and PCMH Frameworks, and to apply the lessons learned from the initial work to the care transitions effort.

Upon deliberation, we selected a set of recommendations that were feasible to complete within the timeframe of this project. These included the majority of suggestions made by the TEPs; only a few suggestions (such as moving the frameworks online) were not addressed. In addition to making changes to the original versions of the PR and PCMH Frameworks, we used these recommendations as we developed the Care Transitions Framework.

## Adapted Contextual Frameworks

The three adapted contextual frameworks maintained many of the essential elements of the CFIR; although a number of domains (the highest taxonomic category in the framework) and constructs (sub-elements of a domain) were renamed, none of the constructs were dropped entirely. A number of noteworthy modifications are described below.

- A Measures of Implementation domain was added to describe the quality or success of the implementation.
- An Outcomes domain was added. The outcomes vary by intervention, although they share some similarities, particularly between the PCMH and Care Transitions Frameworks.
- The CFIR graphic was reconceptualized. The original CFIR graphic attempted to convey the dynamic and permeable interaction among the five CFIR domains (Intervention Characteristics, Inner Setting, Outer Setting, Characteristics of Individuals, and Process). The TEPs' input led us to reconceptualize the graphic and add measures of implementation and outcomes domains. We also expanded the Characteristics of Individuals to include Teams. Figure B presents the final graphic for the PCMH Framework, which is similar to the graphic for the PR Framework (Figure 2 under Process Redesign Framework).
- The graphics for the individual frameworks were reconceptualized. Figure C presents the graphic for the Care Transitions Framework, the furthest departure from the original CFIR. Some TEP members felt the frameworks could better highlight patient needs, preferences, and characteristics, and recommended highlighting patients and providers as discrete entities. To address this feedback, the graphic has separate domains for patients/caregivers and for providers. These domains were further modified by the inclusion of “roles” of providers and patients/caregivers. The PCMH TEP also thought the framework should emphasize the patient more strongly but did not recommend creating a separate domain for patients and providers. The Care Transitions Framework dropped the term “settings,” so Outer Setting was renamed External Context and Internal Setting was renamed Organizational Characteristics.
- Several dozen new constructs were added as part of the adaptation. Many of these new constructs overlap, as the frameworks were developed iteratively. About half of the new constructs are the result of adding the Implementation and Outcome domains. These new constructs and subconstructs are further detailed in Table B using the domain heads for the PR and PCMH Frameworks.

Figure B Framework for Implementation Research on Patient-Centered Medical Homes

Figure ES-2 is a graphic representing the relationship between the domains of the Patient Centered Medical Home Framework. On the left side of the graphic, four domains are shown as four equal quadrants of circle. Starting from the top left quadrant these domains are: intervention characteristics, characteristics of individuals and teams, inner setting and process of implementation. This circle is surrounded by another circle that represents the outer setting domain. These two concentric circles feed into an arrow-shaped box to the right labeled Measures of Implementation. The Measures of Implementation box feeds into an arrow-shaped box on the far right of the figure called Outcomes.

Figure C Framework for Implementation Research on Care Transitions

Figure ES-2 is a graphic representing the relationship between the domains of the Care Transitions Framework. On the left side of the graphic, the following five domains are shown as five equal parts of a circle: intervention characteristics, organizational characteristics, characteristics and roles of providers, characteristics and roles of patients and caregivers, and process of implementation. This circle is surrounded by another circle that represents the external context domain. These two concentric circles feed into an arrow-shaped box to the right labeled Measures of Implementation. The Measures of Implementation box feeds into an arrow-shaped box on the far right of the figure called Outcomes.

Table B New framework constructs

Domain | Construct (Subconstruct) | PR | PCMH | Care Transitions
Intervention Characteristics | Vision and change strategy | ✓^a^ | ✓ | ✓
Intervention Characteristics | Feasibility | ✓^a^ | ✓ | ✓
Intervention Characteristics | Compatibility | ✓^a^ | ✓ | ✓
Intervention Characteristics | Radicalness | ✓^a^ | ✓ | ✓
Intervention Characteristics | User control | ✓^a^ | ✓ | ✓
Intervention Characteristics | Location of PCMH activity (location of intervention activity in Care Transitions Framework) | N/A | ✓^a^ | ✓
Intervention Characteristics | Workflows | ✓^a^ | ✓ | ✓
Intervention Characteristics | Task/process standardization | ✓^a^ | ✓ | ✓
Intervention Characteristics | History | ✓ | ✓^a^ | ✓
Outer Setting | Technological environment | ✓^a^ | ✓ | ✓
Outer Setting | Population needs and resources | N/A | ✓^a^ | ✓
Outer Setting | Community resources | N/A | ✓ | ✓^a^
Inner Setting | (Staff commitment) | ✓^a^ | ✓ | ✓
Inner Setting | IT and HIT resources | ✓^a^ | ✓ | ✓
Inner Setting | (Human factors; HIT/IT accessibility in PCMH Framework) | ✓^a^ | ✓ | N/A
Inner Setting | Physical space and equipment | ✓^a^ | ✓ | N/A
Inner Setting | Staff time | ✓^a^ | ✓ | N/A
Inner Setting | Patient self-management infrastructure | N/A | ✓^a^ | ✓
Inner Setting | Continuity | N/A | ✓ | ✓^a^
Inner Setting | Patient centeredness | N/A | ✓^a^ | ✓
Characteristics of Individuals and Teams | Skills and competencies | ✓^a^ | ✓ | ✓
Characteristics of Individuals and Teams | Role | ✓ | ✓^a^ | ✓
Characteristics of Individuals and Teams | Authority | ✓ | ✓^a^ | ✓
Characteristics of Individuals and Teams | Collective efficacy | ✓ | ✓^a^ | ✓
Characteristics of Individuals and Teams | Socioeconomic demographics | N/A | ✓^a^ | ✓
Characteristics of Individuals and Teams | Patient needs and resources | ✓ | ✓ | ✓^a^
Characteristics of Individuals and Teams | Caregiver needs and resources | N/A | ✓ | ✓^a^
Process of Implementation | Assessing | ✓ | ✓^a^ | ✓
Process of Implementation | Acquiring and allocating resources | ✓ | ✓^a^ | ✓
Process of Implementation | Process ownership | ✓ | ✓ | ✓
Process of Implementation | Engaging organizations, external context | N/A | ✓ | ✓^a^
Process of Implementation | (Organizational leaders) | ✓ | ✓^a^ | ✓
Process of Implementation | (Facilitator) | ✓ | ✓^a^ | ✓
Process of Implementation | (Frontline staff) | ✓ | ✓^a^ | ✓
Process of Implementation | (Integrators) | N/A | N/A | ✓^a^
Process of Implementation | (Patients and other stakeholders) | ✓ | ✓^a^ | ✓
Process of Implementation | (Decisionmaking) | ✓ | ✓^a^ | ✓
Process of Implementation | (Staging and iteration) | ✓^a^ | ✓ | ✓
Process of Implementation | (Measurement capability and data availability) | ✓ | ✓ | ✓^a^
Measures of Implementation | Acceptability | ✓ | ✓ | ✓
Measures of Implementation | Adoption/abandonment | ✓ | ✓ | ✓
Measures of Implementation | Appropriateness | ✓ | ✓ | ✓
Measures of Implementation | Implementation cost | ✓ | ✓ | ✓
Measures of Implementation | Fidelity | ✓ | ✓ | ✓
Measures of Implementation | Reach | ✓ | ✓ | ✓
Measures of Implementation | (Reach within the population) | ✓ | ✓ | ✓^a^
Measures of Implementation | (Reach within the organization) | ✓ | ✓ | ✓^a^
Measures of Implementation | Penetration | ✓ | ✓ | ✓
Measures of Implementation | Replicability | ✓^a^ | ✓ | ✓
Measures of Implementation | Sustainability | ✓ | ✓ | ✓
Measures of Implementation | Evolvability | ✓ | ✓ | ✓^a^
Outcomes | Cost effects/impact | ✓^a^ | ✓ | ✓
Outcomes | Perceived value | ✓^a^ | ✓ | ✓
Outcomes | Unintended consequences | ✓^a^ | ✓ | ✓
Outcomes | Processes of care | N/A | ✓^a^ | ✓
Outcomes | Patient centered | N/A | ✓^a^ | ✓
Outcomes | (Coordinated) | N/A | ✓^a^ | ✓
Outcomes | (Comprehensive) | N/A | ✓^a^ | ✓
Outcomes | (Accessible) | ✓ | ✓^a^ | ✓
Outcomes | (Quality) | ✓ | ✓^a^ | ✓
Outcomes | (Safety) | ✓ | ✓^a^ | ✓
Outcomes | (Effectiveness) | ✓^a^ | ✓ | ✓
Outcomes | (Timeliness) | ✓^a^ | ✓ | ✓
Outcomes | (Efficiency) | ✓^a^ | N/A | N/A
Outcomes | Patient- and caregiver-centered outcomes | N/A | ✓ | ✓^a^
Outcomes | Productivity | ✓^a^ | N/A | N/A
Outcomes | Equitable | ✓^a^ | ✓ | N/A
Outcomes | Patient/caregiver experience | ✓ | ✓^a^ | ✓
Outcomes | Provider experience | ✓ | ✓^a^ | ✓
Outcomes | Clinical outcomes | N/A | ✓^a^ | ✓
Outcomes | Health care utilization | ✓ | ✓^a^ | ✓

a Indicates the original source of the construct or subconstruct.

Note: Subconstructs are shown in parentheses. HIT = health information technology; IT = information technology; N/A = not added; PCMH = patient-centered medical home; PR = process redesign.

## Discussion

Capturing the context of complex system interventions can be daunting, especially because we lack a common taxonomy to describe and understand how the interplay of people, settings, technology, and policy may affect some desired outcome or impact. The CFIR, adapted to the requirements of three types of complex system interventions, is a potential solution to this dilemma.

Using the CFIR to conceptualize the multiple layers of interactions and networks that characterize complex system interventions was difficult because many of the elements of context can vary by time, location, and organizational unit (e.g., individual, team, practice, organization, system). The frameworks in their current form, confined to text-based two-dimensional tables, do not lend themselves to the multiple levels of analysis possible with complex systems. A Web-based tool would make navigation and exploration of the framework easier by allowing the user to adjust views of the framework by domain, construct, and subconstruct, and providing links to their definitions and examples. Other possibilities for examining complex relationships might include exploring the organizational hierarchies (e.g., individual, unit, practice, organization, and system) within a construct and juxtaposing them against one or more dimensions (e.g., practice by location).

The TEPs raised a number of conceptual challenges specific to their intervention area, but a number of the issues they noted are crosscutting and are likely to arise in any similar exercise to describe and conceptualize the context of implementation. These issues include—

- Components of the intervention. A complex system intervention can include an overall redesign strategy (e.g., applying Lean/Toyota Production Systems); tactics (e.g., process mapping); and specific projects (e.g., conducting a rapid-cycle improvement exercise to improve patient throughput in a clinic). Researchers will have to decide where to focus their attention.
- Component of the intervention versus target of the intervention. Elements of the contextual frameworks that are usually thought of as the context within which the intervention occurs, such as climate or leadership, can also become the targets of an intervention.
- Bundled nature of interventions. The interventions can have multiple components (e.g., a practice facilitator coupled with a case manager to coordinate care). A key aim for evaluators is assessing which parts of the bundle were implemented, which parts are associated with outcomes, and the relative importance of the components.
- Intervention timing and research timeframe. The meaning and relevance of constructs are likely to change across stages of implementation. Researchers who follow an intervention over time might retain some core constructs across the entire study but select others that apply chiefly to one stage in the life course of the intervention. Moreover, implementation may be more of an iterative process than a linear one that proceeds sequentially through clear stages.
- Organizational units and level of analysis. Complex system interventions operate at multiple organizational levels (i.e., levels of analysis). Relevant levels may include individual participants, teams, units, organizations (including autonomous practices), and delivery systems. The frameworks may inform research by alerting researchers to the following:
  ○ The importance of conceptualization and measurement at appropriate levels of analysis, and attention to and conceptualization of interactions across levels of analysis and among actors at the same level.
  ○ The importance of weighing potential contributions of multilevel analysis against the need to keep the research within manageable proportions.
- Interaction effects. Several TEP members noted that interactions among elements within the framework may be as important as the effects of isolated variables.
- Alignment of constructs with stakeholder and practice roles. The CFIR distinguishes among the various roles that individuals can assume in implementing an intervention (e.g., leading, facilitating, championing), and our discussion with the TEPs led to the addition of yet other roles. We recognize that constructs may take on different meanings or measured values when applied to different roles.
- Conceptualizing the framework around settings or organizations. Complex system interventions may be broader than a particular practice or integrated health care setting (where patients receive care and treatment) and can include community-based organizations, such as community coalitions, agencies, and collaboratives. These are often the effector arm and critical to care transitions or PCMH interventions. Hence, interventions may be based upon layers of organizations, rather than embedded in a single setting or group of settings.
- Indicators of implementation success. Proctor et al.2 define outcomes of the implementation (e.g., acceptability, adoption, appropriateness, costs, feasibility, preservation, sustainability) as distinct from outcomes of an intervention. The TEP agreed that specifying these implementation outcomes is a useful addition to the framework. To avoid confusion with clinical outcomes, we opted for the term “indicators of implementation success” to refer to Proctor's implementation “outcomes.”
- Intervention outcomes. The PR and PCMH TEPs recommended adding outcomes to the CFIR, although they did not completely agree on which outcomes to include or what to call them. We added intervention-specific outcomes to each of the three frameworks. (Several of the outcomes overlap.) We kept the outcome constructs general to keep the focus of the framework on context and implementation. A large body of literature on many of these outcomes can be used to conceptualize them in more detail.
- Patient-centered/population health perspectives. A number of the PCMH and Care Transitions TEP members thought the draft contextual frameworks should be more patient centered. However, some members of the Care Transitions TEP pointed out that institutional outcomes such as readmissions and cost, rather than patient-centered outcomes such as quality of life, may be a dominant goal. Another consideration related to context is the influence of population health on the intervention design and outcomes.
- Applicability of contextual frameworks to practice. Although originally designed to guide research and evaluation, the PCMH Framework could also incorporate issues of concern to practitioners and managers, and has the possibility of becoming a useful tool for practice.

## Conclusion

The investigative team took a very open approach to this effort, beginning with a literature scan and discussions with AHRQ. Much of the adaptation protocol was developed during the project. We considered other approaches involving more systematic methods (e.g., Delphi) but concluded that a highly systematic approach would not move us toward our desired goal. We did not seek to establish a consensus on every element of the framework; rather, we sought to generate qualitative feedback on the general utility of the framework for complex system interventions. In adapting the CFIR for complex system interventions, we thought it critical to include input from both research and practice stakeholders to ensure that the content is understandable and applicable to the intervention strategy of interest.

Given more time and resources, the frameworks could have been vetted with a broader set of stakeholders and their content honed with more systematic methods. However, we believe the goal of adaptation is not perfection, and care must be taken not to make a framework “endlessly complex”1 for the sake of completeness. We encourage researchers to approach the adaptation process and the frameworks themselves iteratively, and to document and share their experiences with colleagues. Our collective understanding of the complex phenomena we are striving to define, measure, and explain can only increase through such efforts.

## References

1 Damschroder L, Aron D, Keith R, et al. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implement Sci. 2009;4(1):50. [pmid: 19664226].
2 Proctor E, Silmere H, Raghavan R, et al. Outcomes for implementation research: conceptual distinctions, measurement challenges, and research agenda. Adm Policy Ment Health. Mar. 2011;38(2):65-76. [pmid: 20957426].