# Acknowledgments

We gratefully acknowledge the support of the following AHRQ staff—Stephanie Chang, M.D., M.P.H., Christine Chang, M.D., M.P.H, and Michael Harrison, Ph.D., Janice Genevro, Ph.D., Dina Moss, M.P.A., and our Associate Editor, Barbara Mauger, Ph.D. We extend our appreciation to our Senior Advisors (listed below), Technical Expert Panel members (listed below), and Peer Reviewers (listed below), all of whom provided thoughtful advice and input during our assessment process.

We express our gratitude to the following individuals at RTI for their technical contributions to this project: Amy Roussel, Ph.D., Asta Sorensen, M.A., Amy Chepaitis, Ph.D., and Nancy McCall, Sc.D., S.M. The investigators deeply appreciate the considerable support, commitment, and contributions of Carol Offen and Jennifer Drolet, our scientific editors; Susan Beck and Loraine Monroe, our EPC publications specialists; Maria Ashbaugh, our graphic specialist; Christiane Voisin, M.S.L.S., our EPC librarian; Linda Lux, M.P.A., Program Manager; and Allen Zhang, Jennifer Cook Middleton, Ph.D., and Ellen Shanahan, M.A., Research Associates. We extend as well our most sincere gratitude to Laura Damschroder, M.S., M.P.H., Co-Implementation Research Coordinator, Diabetes QUERI at the U.S. Department of Veterans Affairs for her assistance in orienting the Technical Expert Panel members and the investigative team to the Consolidated Framework for Implementation Research (CFIR) and her thoughtful input and engagement throughout the development of this work.