# Discussion

In this chapter, we reflect on the experience of adapting the Consolidated Framework for Implementation Research (CFIR) to three different types of complex system interventions, highlighting the similarities we uncovered in the needs, issues, and concerns voiced by the Technical Expert Panels (TEPs) and guidance we can offer to researchers wishing to adapt the CFIR to other forms of complex system interventions.

The systems in which process redesign for efficiency and cost reduction (PR), patient-centered medical homes (PCMH), and care transition interventions might be applied can aptly be described as nonlinear, dynamic, and composed of a multitude of “massively entangled” entities.33 Most researchers of these interventions (our TEP members among them) would agree that these interventions are complex. Yet we lack a common vocabulary for capturing this complexity. To understand the interplay of people, settings, technology, and policy to effect some desired outcome or impact, researchers require a common taxonomy.

We identified the CFIR, adapted to the requirements of each intervention, as a potential solution to this dilemma. The CFIR draws from a wide range of disciplines and is not tied to any specified theory–features amenable to the study of complex system interventions, which inherently benefit from a multidisciplinary approach. The CFIR's broad range of constructs encompasses most of the contextual dimensions of the three interventions we adapted.

## Similarities and Differences Among the Frameworks

The TEPs found the original constructs in the CFIR to be relevant across the three adaptations. However, the literature scan and the TEP input resulted in adding several dozen new constructs to the PR and PCMH Frameworks and two new domains. The Care Transitions Framework integrated these inputs and added several new constructs of its own, splitting the Individual Characteristics domain into separate domains for providers and for patients and caregivers.

Table 25 presents these new constructs and subconstructs by framework. The original CFIR constructs required mostly modest revisions to the definitions and construct name. The CFIR construct design quality and packaging was dropped from the PR and PCMH Frameworks but retained in the Care Transitions Framework; care transition interventions have packages (e.g., RED [ReEngineered Discharge], Project Better Outcomes for Older adults through Safe Transitions [BOOST]) with established steps and protocols, whereas this is less the case for PR and PCMH.

Table 25 New framework constructs

Domain | Construct (Subconstruct) | PR | PCMH | Care Transitions
Intervention Characteristics | Vision and change strategy | ✓^a^ | ✓ | ✓
Intervention Characteristics | Feasibility | ✓^a^ | ✓ | ✓
Intervention Characteristics | Compatibility | ✓^a^ | ✓ | ✓
Intervention Characteristics | Radicalness | ✓^a^ | ✓ | ✓
Intervention Characteristics | User control | ✓^a^ | ✓ | ✓
Intervention Characteristics | Location of PCMH activity (location of intervention activity in Care Transitions Framework) | N/A | ✓^a^ | ✓
Intervention Characteristics | Workflows | ✓^a^ | ✓ | ✓
Intervention Characteristics | Task/process standardization | ✓^a^ | ✓ | ✓
Intervention Characteristics | History | ✓ | ✓^a^ | ✓
Outer Setting | Technological environment | ✓^a^ | ✓ | ✓
Outer Setting | Population needs and resources | N/A | ✓^a^ | ✓
Outer Setting | Community resources | N/A | ✓ | ✓^a^
Inner Setting | (Staff commitment) | ✓^a^ | ✓ | ✓
Inner Setting | IT and HIT resources | ✓^a^ | ✓ | ✓
Inner Setting | (Human factors; HIT/IT accessibility in PCMH Framework) | ✓^a^ | ✓ | N/A
Inner Setting | Physical space and equipment | ✓^a^ | ✓ | N/A
Inner Setting | Staff time | ✓^a^ | ✓ | N/A
Inner Setting | Patient self-management infrastructure | N/A | ✓^a^ | ✓
Inner Setting | Continuity | N/A | ✓ | ✓^a^
| Patient centeredness | N/A | ✓^a^ | ✓
Characteristics of Individuals and Teams | Skills and competencies | ✓^a^ | ✓ | ✓
Characteristics of Individuals and Teams | Role | ✓ | ✓^a^ | ✓
Characteristics of Individuals and Teams | Authority | ✓ | ✓^a^ | ✓
Characteristics of Individuals and Teams | Collective efficacy | ✓ | ✓^a^ | ✓
Characteristics of Individuals and Teams | Socioeconomic demographics | N/A | ✓^a^ | ✓
Characteristics of Individuals and Teams | Patient needs and resources | ✓ | ✓ | ✓^a^
Characteristics of Individuals and Teams | Caregiver needs and resources | N/A | ✓ | ✓^a^
Process of Implementation | Assessing | ✓ | ✓^a^ | ✓
Process of Implementation | Acquiring and allocating resources | ✓ | ✓^a^ | ✓
Process of Implementation | Process ownership | ✓ | ✓ | ✓
Process of Implementation | Engaging organizations, external context | N/A | ✓ | ✓^a^
Process of Implementation | (Organizational leaders) | ✓ | ✓^a^ | ✓
Process of Implementation | (Facilitator) | ✓ | ✓^a^ | ✓
Process of Implementation | (Frontline staff) | ✓ | ✓^a^ | ✓
Process of Implementation | (Integrators) | N/A | N/A | ✓^a^
Process of Implementation | (Patients and other stakeholders) | ✓ | ✓^a^ | ✓
Process of Implementation | (Decisionmaking) | ✓ | ✓^a^ | ✓
Process of Implementation | (Staging and iteration) | ✓^a^ | ✓ | ✓
Process of Implementation | (Measurement capability and data availability) | ✓ | ✓ | ✓^a^
Measures of Implementation | Acceptability | ✓ | ✓ | ✓
Measures of Implementation | Adoption/abandonment | ✓ | ✓ | ✓
Measures of Implementation | Appropriateness | ✓ | ✓ | ✓
Measures of Implementation | Implementation cost | ✓ | ✓ | ✓
Measures of Implementation | Fidelity | ✓ | ✓ | ✓
Measures of Implementation | Reach | ✓ | ✓ | ✓
Measures of Implementation | (Reach within the population) | ✓ | ✓ | ✓^a^
Measures of Implementation | (Reach within the organization) | ✓ | ✓ | ✓^a^
Measures of Implementation | Penetration | ✓ | ✓ | ✓
Measures of Implementation | Replicability | ✓^a^ | ✓ | ✓
Measures of Implementation | Sustainability | ✓ | ✓ | ✓
Measures of Implementation | Evolvability | ✓ | ✓ | ✓^a^
Outcomes | Cost effects/impact | ✓^a^ | ✓ | ✓
Outcomes | Perceived value | ✓^a^ | ✓ | ✓
Outcomes | Unintended consequences | ✓^a^ | ✓ | ✓
Outcomes | Processes of care | N/A | ✓^a^ | ✓
Outcomes | Patient centered | N/A | ✓^a^ | ✓
Outcomes | (Coordinated) | N/A | ✓^a^ | ✓
Outcomes | (Comprehensive) | N/A | ✓^a^ | ✓
Outcomes | (Accessible) | ✓ | ✓^a^ | ✓
Outcomes | (Quality) | ✓ | ✓^a^ | ✓
Outcomes | (Safety) | ✓ | ✓^a^ | ✓
Outcomes | (Effectiveness) | ✓^a^ | ✓ | ✓
Outcomes | (Timeliness) | ✓^a^ | ✓ | ✓
Outcomes | (Efficiency) | ✓^a^ | N/A | N/A
Outcomes | Patient- and caregiver-centered outcomes | N/A | ✓ | ✓^a^
Outcomes | Productivity | ✓^a^ | N/A | N/A
Outcomes | Equitable | ✓^a^ | ✓ | N/A
Outcomes | Patient/caregiver experience | ✓ | ✓^a^ | ✓
Outcomes | Provider experience | ✓ | ✓^a^ | ✓
Outcomes | Clinical outcomes | N/A | ✓^a^ | ✓
Outcomes | Health care utilization | ✓ | ✓^a^ | ✓

a Indicates the original source of the construct or subconstruct.

Note: Subconstructs are shown in parentheses. HIT = health information technology; IT = information technology; N/A = not added; PCMH = patient-centered medical home; PR = process redesign.

Our decision to include some constructs in a framework and not others was dictated by our understanding (informed by experts and the literature scan) of the principal focus of the intervention. The PR Framework, for example, did not add many of the patient- and population-focused constructs (e.g., population needs and resources, continuity of patient care, socioeconomic demographics) because generally PR studies on improving efficiency and reducing costs emphasize reducing waste and producing more units of service or output with less (or the same) resources. Ensuring that the PR improves patient outcomes (or at least does not worsen them) could be an explicit outcome, as reflected in the inclusion of patient needs and resources, patients and other stakeholders, and patient-related PR Framework outcomes.

Similarly, efficiency as an outcome was not added to the PCMH Framework and Care Transitions Framework because the major focus of these interventions is on enhancing patient experiences and outcomes, and perhaps less on increasing the throughput of patients through the system or decreasing the number of steps to complete a task. The integrator role was not added to the PR and PCMH Frameworks because central coordination of many different types of organizations and roles outside the implementing organization is not a defining feature of these interventions. The IT/HIT (information technology/health information technology) accessibility role was not added to the Care Transitions Framework because we deemed technology a facilitator but not a key driver or focus of the intervention. Obviously, the specific goals of a particular investigation may require the inclusion of a construct not added to the framework, and we encourage investigators to approach the frameworks with a degree of flexibility and openness.

Using the CFIR to conceptualize the multiple layers and complex interactions and networks that characterize complex system interventions was more difficult. Many of the elements of context can vary by time, location, and organizational unit (e.g., individual, team, practice, organization, system). This limitation of the framework became especially apparent in the care transitions area, as these interventions cannot even be characterized as having a narrowly defined location or setting. Interventions that are essentially a multiagency collaborative or a community-based entity that provides coordination across multiple providers are not bounded by place or organization. In this case the TEP had difficulty distinguishing the “outer setting” from the “inner setting.” Accordingly, we dropped the term “inner setting” altogether from the Care Transitions Framework and regrouped its constituent parts into new domains.

In the initial versions of the PR and PCMH Frameworks, we included samples of constructs in two- and three-dimensional tables to orient the researcher to the multidimensional attributes of constructs and to discourage the tunnel vision that can occur when context is examined from only one perspective. These sample tables failed to resonate with the TEPs, who found them on the whole confusing and unhelpful. The frameworks in their current form, confined to text-based two-dimensional tables, do not lend themselves to the levels of abstraction possible with complex systems. A Web-based tool that allows the user to explore the various hierarchies within a construct and juxtapose them against two or more dimensions (e.g., time by location) may come closer to achieving the original intent of our sample tables.

The frameworks, due to the breadth and relevance of the constructs included, should acquaint the researcher or the implementing organization with the large range of contextual variables that are possible and important to consider in a study or evaluation. The frameworks can be used by investigative teams planning multisite studies or funders supporting a portfolio of grants to deliberate on the core constructs needed for cross-site analysis. However, we recognize that the sheer number of constructs can be overwhelming, and at the TEPs' suggestion we added a general roadmap to guide the construct selection process. As every study is unique, there is no simple recipe for construct selection. Much like the interventions, the decision to include or leave out specific constructs is rooted in the context of the study itself.

## Crosscutting Issues

CFIR was originally developed for research on highly focused clinical and practice interventions, rather than for evaluations of complex sets of interventions such as the three discussed here. Adapting the CFIR is therefore challenging but is needed if the framework is to contribute to research on the complex system interventions that are spreading and evolving rapidly.

In the remainder of this chapter, we present a number of the common issues or concerns we encountered in two or more of the adaptations. Some of these we addressed in the frameworks. Others remain unresolved or may have no clear solution, but are nevertheless important to keep in mind. These issues are as follows:

- Components of the intervention. Complex system interventions are typically not a single intervention but a collection of interventions, so issues of scope and boundary are critical to address early in study design. PR interventions such as Lean and Six Sigma can be especially confounding because they are organization-wide initiatives; researchers must decide whether to apply particular constructs (e.g., complexity and relative advantage of intervention) organization-wide, to specific projects, or both.
- Components of the intervention versus targets of the intervention. Disentangling the intervention from its context for research purposes can be an onerous task. Elements of the framework that are usually considered to be the context within which an intervention occurs can also become the targets of an intervention—for example, when PR seeks to alter team interactions or change culture and learning climate. Defining exactly what elements constitute the intervention and its objectives would seem a critical first step in using the framework. Unless the intervention specifies a specific causal pathway with well-articulated goals and objectives, the activities or outputs of the intervention could easily be confused with the outcomes. A new “vision/change strategy” construct was added to distinguish the intervention from its context.
- Bundled nature of many interventions. The bundling of intervention components drawn from different programs is a key element in these interventions. Bundling is important for evaluating which parts of the bundle were implemented, which parts are associated with outcomes, and the relative importance of the components.
- Intervention timing and research timeframe. Complex system interventions rarely have a defined start and end date. As several TEP members noted, implementation may be more of an iterative process than a linear one that proceeds sequentially through clear stages. The PR and PCMH TEPs agreed that the contextual framework should encourage awareness of possible changes in the meaning and relevance of constructs across stages of implementation—even though very little empirical knowledge exists about the long-term implementation of complex interventions. One conceptualization that may be helpful divides the process into three stages: preimplementation, implementation, and sustainability.34 Constructs that are relevant to one stage, such as preimplementation adoption decisions, may be less useful for studying another stage of the same intervention, such as sustainability. Researchers who follow an intervention over time might retain some core constructs across the entire study but select others that apply chiefly to one stage in the life course of the intervention. While considerations of time are relevant to selecting and applying constructs, the TEP noted that it can be difficult to determine when adoption and other stages begin and end.
- Organizational units and level of analysis. Complex system interventions may occur in multiple organizational units at the same time. For example, several clinics within the same organization or delivery system may implement similar redesigns aimed at enhancing patient access and throughput. Additionally, redesigns often operate at multiple organizational levels (i.e., levels of analysis). Relevant levels may include individual participants, teams, units, organizations (including autonomous practices), and delivery systems. The framework may inform research by alerting researchers to the following:
  ○ The importance of conceptualization and measurement at appropriate levels of analysis, and attention to and conceptualization of interactions among actors or units at the same level and across levels.
  ○ The importance of weighing potential contributions of multilevel analysis against the need to keep the research within manageable proportions.
- Interaction effects. Several TEP members noted that such interactions, along with interactions among multiple aspects of the interventions (reflected in multiple constructs within the framework), may be as important as the effects of isolated variables.
- Alignment of constructs with stakeholder and practice roles. The CFIR distinguishes among the various roles that individuals can assume in implementing an intervention (e.g., leading, facilitating, championing), and our discussion with the TEPs led to the addition of yet other roles and to a focus on the diverse internal and external stakeholders involved in and affected by PR, PCMH, and care transitions. We recognize that constructs may take on different meanings or measured values when applied to different roles or different stakeholders. For example, top management and nurse leaders may assess the value of an intervention of nursing roles very differently. External change agents for an intervention may assess the leadership commitment to the intervention very differently than frontline staff who participate in the initiative.
- Indicators of implementation success. Proctor et al.5 define outcomes for the implementation (e.g., acceptability, adoption, appropriateness, costs, feasibility, preservation, sustainability) as distinct from the outcomes of an intervention. The TEP agreed that specifying these implementation outcomes is a useful addition to the framework. To avoid confusion with clinical outcomes, we opted for the term “indicators of implementation success” to refer to Proctor's implementation “outcomes.”
- Intervention outcomes. The PR and PCMH TEPs recommended adding outcomes to the CFIR, although they did not completely agree on which outcomes to include or what to call them. We added intervention-specific outcomes to each of the three frameworks. (Several of the outcomes overlap.) We kept the outcome constructs general so as to keep the focus of the framework on context and implementation. A large body of literature on many of these outcomes can be used to conceptualize them in more detail.
- Patient-centered/population health perspectives. Neither the PCMH nor the Care Transitions TEPs thought the frameworks were sufficiently patient centered. On the one hand, intervention design is usually centered around organizations, based on issues such as policies, payment, speed, funding, and research opportunities, and organizations are the leaders of this work; institutional outcomes such as readmissions and cost, rather than patient-centered outcomes such as quality of life, are usually the primary goal. On the other hand, the primary reason for a PCMH or care transitions intervention is the patient, and if the intervention cannot be personalized to heterogeneous patient and caregiver needs, it will not be effective. The PCMH and Care Transitions TEP members also felt that the framework should emphasize the role of population health. Taking into account these perspectives, we added constructs relevant to patient-, caregiver-, and population-level contexts. We also included patient outcomes.
- Conceptualizing the framework around settings or organizations. Complex system interventions are broader than a particular practice or integrated health care setting (where patients receive care and treatment) and typically can include community-based organizations, such as community coalitions, agencies, and collaboratives. These are often the effector arm and critical to a care transitions or PCMH intervention. A key concept to consider is that the intervention is based upon layers of organizations, rather than embedded in a single setting or group of settings.
- Broader applicability. Although the primary purpose of the frameworks is to guide research and evaluation, a number of TEP members thought they incorporated issues of concern to implementers and might become a useful tool for practice.

## Limitations

The comprehensive series of methods used to develop the PR, PCMH, and Care Transitions Frameworks has a number of strengths, including a set of literature reviews and TEP input sessions. Limitations include the scope of the literature reviews, which could have missed some relevant resources (e.g., by focusing on hospital-ambulatory transitions or searching after 2005 for care transitions interventions), and limitations on the size of the TEPs to group sizes amenable to discussion, which may have not included some viewpoints. The qualitative, descriptive nature of the input allowed for a rich discussion of the issues, but interpretations of recommendations were made based on discussion; no surveys or other quantitative input was obtained from the TEP. The scope of this project did not include a formal assessment of the validity of each construct or identification and development of measures. We point investigators interested in measurement to the Seattle Implementation Research Collaborative, which has undertaken a formal evaluation of over 400 instruments for implementation research (www.seattleimplementation.org/sirc-projects/sirc-instrument-project/). Finally, although we asked the TEPs to consider carefully if and how they would apply the frameworks to their implementation research, real evaluation of these frameworks depends on application in actual practice.

## Next Steps

The adoption and use of the frameworks could be facilitated through a number of next steps. First, a Web-based version of the frameworks that allows users to drill down to the level of detail desired would allow the frameworks to be as comprehensive as needed without being overwhelming in detail. Second, evaluation of the user experience with the framework in a real-world research setting would provide valuable feedback for improving and developing the framework further. Third, the evaluation could be used to create an interactive roadmap that would provide users with tailored guidance on which constructs to select for specific research goals, as well as to link constructs to candidate measures. Transforming a static two-dimensional framework into a decision support tool for investigators would be a significant undertaking, but one well worth considering in view of the potential for improving the comparability and rigor of implementation studies.