# Conclusion

The investigative team took a very open approach to this effort, with a literature scan and discussions with the Agency for Healthcare Research and Quality and our Technical Expert Panels. Much of the adaptation protocol was developed during the project. We considered other approaches involving more systematic methods (e.g., Delphi), but concluded that a highly systematic approach would not move us toward our desired goal. We did not seek to establish a consensus on every element of the framework; rather, we sought to generate qualitative feedback on the general utility of the framework for complex system interventions. In adapting the Consolidated Framework for Implementation Research (CFIR) for complex system interventions, we thought it critical to include input from both research and practice stakeholders to ensure that the content is understandable and applicable to the intervention strategy of interest.

The process of adapting the CFIR to three complex system interventions proved to be a daunting but stimulating challenge, and it pushed the investigative team to think creatively about how to produce a usable product for research implementation with rigor and efficiency. Given more time and resources, the frameworks could have been vetted with a broader set of stakeholders and their content honed with more systematic methods. However, we believe the goal of adaptation is not perfection, and care must be taken not to make a framework “endlessly complex”3 for the sake of completeness. We encourage researchers to approach the adaptation process, and the frameworks themselves, iteratively and to document and share their experiences with colleagues. Our collective understanding of the complex phenomena we are striving to define, measure, and explain can only increase through such efforts.