# Care Transitions Framework

## Overview^d^ d Because the three frameworks are described in stand-alone chapters, the Overview and Organization sections are similar across the chapters.

Care transitions can be defined as “the movement patients make between health care practitioners and settings as their condition and care needs change during the course of a chronic or acute illness.”29 Interventions to improve transitions or transitional care are “a set of actions designed to ensure the coordination and continuity of health care as patients transfer between different locations or different levels of care within the same location.”30

The Care Transitions Framework presented here builds on previous adaptations of the Consolidated Framework for Implementation Research (CFIR)3 for process redesign for efficiency and cost reduction (PR Framework) and patient-centered medical homes (PCMH Framework). The purpose of the framework is to guide research and evaluation of care transitions implementation within a broad range of organizational settings to address questions of how, why, and where care transitions interventions succeed or fail to achieve intended outcomes, and whether the framework components can be replicated and scaled to other settings. Investigators can apply the Care Transitions Framework to a whole intervention with various distinct parts, or to one or more of those parts. The primary users of this framework are investigators and practitioners who wish to design a study or evaluation project.

A key focus of current health care policy is interventions for transitions from the acute hospital to the ambulatory setting, which can involve predischarge interventions in the hospital setting, such as patient/caregiver education; postdischarge interventions, such as outreach to patients; and bridging interventions, which include both types of elements. The Center for Medicare & Medicaid Innovation (CMMI) has also recently funded projects that integrate community-based organizations and services into new care delivery models for beneficiaries. The inclusion of a strong community component to these models requires close attention to the context and interactions of organizational stakeholders.

The taxonomy used in several previous systematic literature reviews on care transitions31 categorizes different types of transitional care interventions and includes key activities (or components) from the perspective of the hospital. Importantly, because this taxonomy (and most current research) is from the hospital perspective and therefore does not address community-based interventions comprehensively, we have not included the development of relationships with common postdischarge followup sources, outpatient-based care management, or primary care interventions.

This chapter is organized into six sections. The first section briefly describes the domains of the Care Transitions Framework. It is followed by a discussion of how we adapted and refined the PR and PCMH Frameworks to care transitions interventions. The Care Transitions Framework is next presented in two forms, a graphic followed by a full explication of the domains, constructs, and subconstructs in Tables 18 through 24. The How To Use section gives users a step-by-step roadmap for approaching the multiple and complex dimensions of the framework. This chapter concludes with a case study of a care transitions intervention that applies the roadmap. See the Glossary for important terms.

Table 18 Care Transitions Framework—Intervention Characteristics

Construct | Description | Examples
A. Vision and change strategy (NEW) | The proposed changes envisioned by the intervention and the theory of change: how the intervention is supposed to work, what it is meant to achieve or do.6 May be explicated in logic models, goals, outcomes, performance measures. | According to Complex Adaptive System (CAS) theory, a designated integrator can improve quality of communication among organizations, which will result in process improvement.27
B. Targeted groups | Staff and others (vendors, patients) who are the intended recipients or beneficiaries of the intervention. | —
C. Intervention source | Identifying who (which individuals or groups) originated the initiative and/or the source from which the components of the initiative were derived. | —
D. Evidence strength and quality | Target group and other stakeholders' perceptions of the quality and validity of evidence supporting the belief that the intervention will have the desired outcomes.8 | Peer-reviewed published literature; consensus policy statements.
E. Relative advantage | Target group and other stakeholders' perceptions of the advantage of the selected intervention instead of other possible interventions or maintaining the status quo.7 | —
F. Feasibility (NEW) | Target group and other stakeholders' perceptions of the extent to which the intervention can be successfully used or carried out within the organization(s). | —
G. Adaptability | Target group and other stakeholders' perceptions of the degree to which the intervention can be adapted to meet local needs. | —
H. Trialability | Target group and other stakeholders' perceptions of the ability to test components of the intervention on a small scale in the organization(s). | —
I. Complexity | Target group and stakeholders' perception of the duration, scope, centrality, and intricacy, and number of steps and organizations required to implement the intervention. | Packaged bundle of complementary activities vs. single activity (e.g., discharge planning).
J. Compatibility (NEW) | Target group and stakeholder perception of the alignment of the meaning, values, and norms attached to care transitions with those held by members of the organization(s).21 | —
K. Radicalness (NEW) | Target group and other stakeholder perceptions of the degree of difference between the change envisioned and the current state of care transitions.9 | —
L. User control (NEW) | The degree to which the intervention relies on the end-users' authority/skill to implement the intervention on their own vs. reliance on experts. | —
M Location of intervention activity (NEW) | Components of the intervention conducted outside the hospital/clinic/office setting using external service providers and organizations. | Case management, phone followup, home visits.
N. Design quality and packaging | Degree to which interventions within a bundle or program are well specified and well aligned with one another | A standardized intervention such as Project RED (Re-Engineered Discharge).
O. Workflows (NEW) | Tasks and workflows, including interdependencies between them that are the focus of the intervention or will be affected by it.7 | Medication reconciliation, outreach to patients.
P. Task/process standardization (NEW) | Degree to which the intervention seeks to standardize tasks and processes that require iterative consultation. | —
Q. History (NEW) | Experiences with similar interventions within the organizations or within the target groups. | The maturity, breadth, and depth of collaboration with community service agencies.

Table 19 Care Transitions Framework—External Context

Construct | Description | Examples
A. External networks | Involvement with organizations, systems, and partnerships that support and promote care transitions. | Improvement collaborative; aging and disability networks.
B. External pressure | Pressure emanating from outside the organization to implement the intervention. | Key peer or competing organizations have implemented care transitions.
C. External policy and incentives/disincentives | Laws and regulations (governmental or other central entity), recommendations and guidelines, and payment schemes that affect decision to adopt or abandon the intervention. | Affordable Care Act; nonpayment for readmissions.
D. Technological environment (NEW) | The technological trends and movements and the availability of technological innovations that may affect the intervention and its context. | Electronic medical record compatibility, health information exchange, social media.
E. Population needs and resources (NEW) | Prevalence of conditions and disease in the population served and the characteristics of the community that are determinants of health status. | Interventions more critical in populations with high rates of chronic disease.
F. Community resources (NEW) | Availability and access of service providers, aging resources, and multiple levels of community services and supports not directly involved in the intervention. | Services for subacute rehabilitation.

Table 20 Care Transitions Framework—Organizational Characteristics

Construct | Description | Examples
A. Structural characteristics | Social architecture, age, maturity, size, and composition of the organization(s). | —
B. Team and network characteristics | Influence, breadth, depth, and role diversity of the teams and networks engaged in the intervention.11 | Linkages between providers, units, the hospital and ambulatory setting, and other involved organizations, and ability to navigate among them.
B1. Teams, networks, and communications | Nature and quality of teams and social networks; formal/informal communication and information exchange within and across organization(s), with patients and caregivers. | —
B2. Team and network self-organization | Capacity to arrange and organize for a defined (nonrandom) purpose without external pressure or mandate. | —
C. Culture | Norms, values, and basic assumptions of given unit(s) or organization(s) that affect views of the intervention and its implementation. | —
D. Implementation climate | Capacity or reserve for change and the shared receptivity of involved individuals to the intervention.12 | —
D1. Tension for change | Degree to which stakeholders perceive the current situation as intolerable or needing change. | —
D2. Mandate | Whether compliance with the intervention is expected within the organization. | —
D3. Accountability | Whether entities are subject to tangible consequences for noncompliance. | —
D4. Relative priority | Individuals' shared perception of the importance of the intervention and its components within the organization(s). | —
D5. Organizational incentives | Extrinsic incentives and rewards offered to implement the intervention. | —
D6. Learning climate (NEW) | Organization's willingness to promote trial and error, test new methods, and innovate.11 | —
E. Readiness for implementation | Tangible and immediate indicators of organizational commitment to its decision to implement care transitions. | —
E1. Leadership engagement | Degree of commitment and accountability of leaders and managers to high-quality care transitions, and specifically to the intervention components. | —
E2. Staff commitment (NEW) | The degree of clinician, transitional, and community care staff, patient, and caregiver involvement in transition planning. | Degree of clinician and staff participation in training.
F. Access to information, training, education | Ease of access to digestible, applicable information about the intervention. Resources dedicated to training and education available within the organization. | Online training tools, time given for training and education, funding for training.
G. IT and HIT resources (NEW) | Technological infrastructure in place to support electronic information management, including IT that crosses organizations. | —
G1. HIT systems | Electronic information management infrastructure and technologies available to clinicians to manage patient care, data, and communications. | Decision support tools, e-prescribing, electronic health records.
G2. IT systems | Technological systems and capabilities to support care transitions. | Interoperability, health information exchange.
G3. HIT/IT accessibility (NEW) | Includes features of the physical, technical, and social environment in the organization that determine the use, accessibility, and acceptability of technology in patient care.13 | —
H. Physical space and presence of organizations | Physical space and equipment dedicated to or impacted by the intervention.14 | Designated space for team meetings. Office space for community-based transitional care staff at the hospital.
I. Staff time | Staff time dedicated to implement the intervention. | Time given to staff to attend training and learn transition procedures.
J. Other resources (NEW) | Resources for implementation and ongoing operations to support change and innovation, including grant or other funding specific to care transitions. | Money, physical space, equipment, staff time.
K. Patient self-management infrastructure (NEW) | Training, counseling, and education available to patients [underlined: prior] to the intervention within the hospital and ambulatory setting. | —
L. Continuity (NEW) | Information continuity (exchange of information) and relationship continuity, both with providers and patients/caregivers and across organizations. | —
M. Patient/caregiver-centeredness (NEW) | Extent to which the organization(s) knows and prioritizes patient and caregiver goals, needs, and preferences, and has the resources and services to meet them. | —

Note: HIT = health information technology; IT = information technology.

Table 21 Care Transitions Framework—Characteristics and Roles of Providers, Patients, and Caregivers

Construct | Description | Examples
A. Knowledge and beliefs | Individual attitudes toward and value placed on the intervention as well as familiarity with facts, truths, and principles related to the intervention. | —
B. Skills and competencies (NEW) | Degree of relevant subject matter expertise, skills, and competencies within the implementing team, unit, and organization. | —
C. Role (NEW) | Individual's role and responsibility for the intervention. The degree of multiple or shared roles. | Patient is expected to meet with a patient navigator monthly and can make appointments.
D. Authority (NEW) | Individual provider's perceived and actual degree of authority to make decisions and act autonomously.15 | —
E. Self-efficacy | Individual provider's belief and confidence in his/her capacity to execute the courses of action necessary to achieve intervention goals. | —
F. Collective efficacy (NEW) | Conviction of individuals and teams involved that the intervention can be carried out in cooperation with each other.16 | Case manager does not believe the providers have the time to deal with patient issues.
G. Stage of change | Characterization of the phase an individual is in, as he or she progresses toward skilled, enthusiastic, and sustained application of the intervention. | —
H. Identification with organization(s) | How individuals perceive the implementing organization(s) and the degree of attachment to those organizations. | Patients' trust in their usual source of care vs. a new case management service.
I. Socioeconomic demographics (NEW) | Characteristics related to the individual's socioeconomic status. | Age, race, gender, occupation, insurance status.
J. Patient needs and resources (NEW) | Patient priorities for health and health care priorities and the social and economic capital to address those priorities. | Importance of self-management, need for care coordination. Preferences for caregiver involvement in discharge planning.
K. Caregiver needs and resources (NEW) | Caregiver priorities for health and health care, and the social and economic capital to address those priorities. | Caregivers' desire to engage with other caregivers through support groups.
L. Other personal attributes | Other personal traits not captured elsewhere. | Tolerance of change, social network support, quality of relationship between patient and caregiver.

Table 22 Care Transitions Framework—Process of Implementation

Construct | Description | Examples
A. Planning | Degree to which implementation steps or tasks are developed in advance; the quality of those schemes or methods. | —
A1. Assessing (NEW) | Formal assessment of care transitions issues; the needs of the users; barriers to change; the timing of these activities relative to implementation. | Root cause analysis.
A2. Goal-setting | Written goals, objectives, benchmarks, and timeline activities and their feasibility and adequacy. | —
A3. Feedback | Procedures used to provide feedback to stakeholders.
A4. Contingency planning (NEW) | Plans for adaptation in response to various scenarios and outcomes. | Plans for increasing the availability of resources to meet the demands of implementation.
B. Acquiring and allocating resources (NEW) | Resources dedicated to implementing the intervention; the adequacy of those allocations. | —
C. Process ownership (NEW) | The diversity of transition roles involved in processes of implementation; authority and accountability for these activities. | —
D. Transition roles (NEW) | Roles of individuals involved in the decision to adopt, execute, and facilitate the intervention. | Case managers, navigators, social service providers.
D1. Organizational leaders (NEW) | Managers and others with the authority to dedicate resources and make decisions to adopt, maintain, or abandon the implementation. | —
D2. Opinion leaders | Individuals who influence (positively or negatively) the attitudes and beliefs of their colleagues.17,18 | Experts and peers.19
D3. Formally appointed implementation leaders | Individuals formally appointed with responsibility for implementing the intervention. | Program manager.
D4. Champions | Individuals who dedicate themselves to galvanizing and maintaining support for the intervention and overcoming indifference or resistance. | —
D5. External change agents | Individuals outside the organization who can facilitate or undermine decisions about adoption and implementation. | Individuals from health plans, other health care systems, collaboratives, consultants, and policymakers.
D6. Frontline staff (NEW) | Administrative staff, providers (within and outside the organization) who will carry out the intervention or be affected by it. | —
D7. Integrators (NEW) | Individuals who build relationships between organizations and create linkages to facilitate the intervention. | —
D8. Patients, caregivers, and other stakeholders (NEW) | Patient and his/her family members, and members of the family's support network. | —
E. Engaging | Processes involved in attracting and involving appropriate individuals in the implementation and use of the intervention.10 | Patient facilitation, navigation, outreach, and followup across organizations.
E1. Engaging organizations, external context (NEW) | Developing and capitalizing on relationships with providers, leaders, and frontline staff in the implementing organizations, and to external providers, resources, funders. | —
F. Executing | Extent to which those involved carry out and accomplish the implementation according to plan; the role and authority to execute.15 | —
F1. Decisionmaking (NEW) | Frequency, duration, and timing of the activities involved in making decisions.11 The directionality of these activities.20 | Decisions made with the patient vs. for the patient.
F2. Staging and iteration (NEW) | Degree to which the care transition is carried out in iterative, incremental steps or implemented in its entirety within a specified period. | —
G. Reflecting and evaluating | Quantitative and qualitative feedback on the quality of the implementation process21^—^“reflexive monitoring” and the degree to which it is attained. | Project monitoring; systematic feedback processes.
G1. Measurement capability and data availability (NEW) | Availability of timely data. Capacity for monitoring, evaluation, and process improvement. Includes measurement differences; accountability for collection, documentation, and analysis. | Better Outcomes for Older adults through Safe Transitions (BOOST) includes easy-to-aggregate measures.

Table 23 Care Transitions Framework—Measures of Implementation (new domain)

Construct | Description | Examples
A. Acceptability (NEW)2 | Degree to which intervention goals, strategies, tactics, and specific activities are agreeable, palatable, or satisfactory. | —
B. Adoption/abandonment (NEW)2 | Intention, initial decision, or action to employ or cease the intervention. | —
C. Appropriateness (NEW)2 | Suitability of the intervention to the specific transition issues or problems to be addressed. | —
D. Intervention cost2 | Costs of the intervention and costs associated with implementing that intervention, including investment, supply, and opportunity costs. | —
E. Fidelity (NEW)2 | Degree to which the intervention was implemented as originally designed by those who developed and/or introduced it to the organization. | —
F. Reach (NEW) | Absolute number, proportion, and representativeness of entities who are willing to participate in a given initiative, intervention, or program.22 | —
F1. Reach within the population (NEW) | Number of patients within the targeted setting exposed to or participating in the intervention. | Percentage of patients who receive a discharge plan.
F2. Reach within the organization (NEW) | Absolute number, proportion, and representativeness of individuals and subcomponents within an organization setting exposed to or participating in the intervention.22 | Percentage of units within a hospital that use discharge planning.
G. Penetration (NEW)2 | Depth of integration of the intervention within an organization involved in the intervention and its subsystems. | Percentage of time a discharge document is transmitted to the accepting provider.
H. Replicability(NEW) | Degree to which the intervention implementation process and outcomes can be reproduced beyond the adopting sites or settings. | —
I. Sustainability (NEW)2 | Extent to which changes resulting from the intervention are maintained or institutionalized within the organization(s)' ongoing, stable operations. | —
J. Evolvability (NEW) | Extent to which the change is capable of being sustained through adaptation and refinement. | —

Table 24 Care Transitions Framework—Outcomes (new domain)

Construct | Description | Examples
A. Patient- and caregiver-centered outcomes (NEW) | Patient- and caregiver-defined goals and care consistent with patient and caregiver preferences. | Patient and caregiver would rather be catheterized in the hospital than at home or would rather be seen by a physician than by a nurse practitioner.
B. Patient/caregiver experience (NEW) | Impact of the intervention on patient/caregiver experiences with care, including satisfaction with care and patient/caregiver-provider interactions.21 | —
C. Provider experience (NEW) | Effect(s) of the intervention on a provider's burden of effort and quality of work life, including provider communication/collaboration.21 | —
D. Processes of care (NEW) | Key measurable processes of care transitions interventions. | —
D1. Patient-centered (NEW) | Extent to which intervention engages patients and family in care decisions, provides resources for self-care, and is culturally and linguistically appropriate.23 | Collaborates with patients and family to develop care plans.
D2. Coordinated (NEW) | Extent to which the intervention tracks discharged patients; follows up on and coordinates tests, referrals, and care across organizations/settings.23 | —
D3. Comprehensive (NEW) | Extent to which the intervention satisfies all the health care needs of a patient, including prevention and specialty care.24 Includes access and ability to pay. | —
D4. Accessible (NEW) | Extent to which routine/urgent care and clinical advice are delivered during and after business hours, and electronic access is provided.23 | —
D5. Quality (NEW) | Extent to which the intervention shows an ongoing commitment to high quality through the use of performance measurement, evidence-based strategies, etc.24 | —
D6. Safety (NEW) | Extent to which the intervention collects and uses safety data, and shares such data publicly as a marker of ongoing commitment to safety and quality.24 | —
E. Effectiveness (NEW)3 | Extent to which the intervention contributes to providing services to all who could benefit, without providing services to those who would not. | —
F. Timeliness (NEW)3 | Extent to which the intervention contributes to reducing wait times and delays, both for those who provide care and those who receive it. | —
G. Clinical outcomes (NEW) | Result of a medical intervention as captured by changes in health status. | —
H. Health care utilization (NEW) | Utilization related to care transitions, such as readmissions, redundant tests/procedures, and postdischarge provider visits. | —
I. Cost effects/impact (NEW) | Cost impact (summative or incremental) resulting from intervention changes. Fixed and variable costs; offsets of the cost of implementation. | —
J. Value (NEW) | Perceived worth, utility, and importance of intervention outcomes for the organization, providers, and patients. | —
K. Unintended consequences (NEW) | Emergent, interim, or longer term outcomes that were unanticipated and usually not desired. | —

## Organization of the Care Transitions Framework

The Care Transitions Framework is a comprehensive menu of implementation research factors, organized into eight domains and subdivided into more specific categories of constructs and subconstructs. The domains differ from the CFIR and the PR and PCMH Frameworks in several ways. Care transition interventions often cover multiple settings, so the Outer Setting is redefined here as the External Context, and because the intervention can involve more than just settings (e.g., community-based organizations), the Inner Setting is redefined as Organizational Characteristics. The Outcomes domain, which was added for the PCMH Framework, is also included. The eight domains, adapted from CFIR and the PR and PCMH Frameworks, are defined as follows:

- Intervention Characteristics: The characteristics and features of the intervention being implemented in a particular organization(s), including core activities or components (the essential and indispensable elements of the intervention itself). These may be fixed or mutable attributes; they are considered and assessed prior to implementation and influence adoption decisions.
- External Context: The economic, political, and social context within which an organization or organizations reside and that may affect the implementation process.
- Organizational Characteristics: Redefined from the CFIR “Inner Setting” domain. Tangible and intangible manifestations of characteristics of the organizations involved in the intervention, including structural characteristics, networks and communications, culture, climate, and readiness, which all interrelate and influence implementation. The construct includes hospital and ambulatory organizations involved in the care transitions intervention, as well as other organizations that are core to the intervention (e.g., community-based organizations). Can include the transferring and receiving organizations.
- Characteristics and Roles of Providers: Attributes of the individuals (as carriers of cultural, organizational, professional, and individual mindsets, norms, interests, and affiliations) who are engaged in the provision of care or treatment. They may or may not be directly involved in the intervention and/or implementation process.
- Characteristics and Roles of Patients and Caregivers: Attributes (individual mindsets, norms, interests, and affiliations) of the individuals and caregivers who are the recipients of care or treatment in the given intervention setting.
- Process of Implementation: Processes (including planning, engaging, and reflecting) to achieve individual- and organizational-level use of the intervention as designed.
- Measures of Implementation: Qualities of the implementation and descriptions of how the intervention components are actually implemented within and between organizations, and changes over time. Measurement should involve not just the number and type of interactions with patients and caregivers or between providers, but the content and quality of those interactions. These elements refer to the Proctor et al.5 “implementation outcomes”; they are intermediate outcomes.
- Outcomes: The results of the implementation, defined as implementation dimensions, and the targets of the intervention overall.

Researchers could use this framework to define and review the range of potentially relevant concepts and outcomes as they prepare an implementation study. Additionally, they could conduct initial investigations with hospital and ambulatory care providers, administrators, and implementers to determine which constructs are likely to be most useful in the evaluation. During their research, they may refine their selection of constructs and their specifications of them in response to data that emerge from the field or in response to changes in the intervention process and context that take place during the life course of the intervention. They may also find it useful to refine the subconstructs even further for specific research purposes.

## Modifications in the Care Transitions Framework

The original intent of the Care Transitions Framework was to focus on transitions from hospital to ambulatory care settings; however, the Technical Expert Panel recommended including community-based service organizations because these entities play central roles in the successful transition to the home. Ultimately we chose to broaden the focus and emphasize interactions between organizations, reframing constructs to include different organizations within an intervention, increasing emphasis on patients and engagement, and adding and separating out caregiver issues. Below, we provide a brief discussion of domains and constructs that were developed or modified substantially for the Care Transitions Framework. All construct and subconstruct additions/modifications are noted in Table B in the Executive Summary and Table 25 in the Discussion. For definitions of these constructs, see the Care Transitions Framework tables, which begin with Table 18.

- Intervention Characteristics: The CFIR construct adaptability was adapted to reflect the frequent need to choose different components that are contained within a “bundled” intervention in care transitions interventions. Organizations using a named intervention such as STAAR (State Action on Avoidable Rehospitalizations) have frequently customized it. Rather than using labels, it is better for the researcher to precisely describe what is being done.
- External Context: This domain was renamed from Outer Setting, as these interventions will often include different settings. Care transitions rely heavily on community resources, so this construct was added.
- Organizational Characteristics: The Technical Expert Panel agreed that the framework should be broader than practice or integrated health care settings (where patients receive care and treatment) and include community-based organizations, such as community coalitions, agencies, and collaboratives. Thus, this domain was renamed from Inner Setting, as these interventions can include different settings as well as other organizations, such as community-based organizations or collaboratives. We also had numerous modifications and additions to this domain.
  ○ Accountability was modified to reflect the shared accountability for implementation and success across and within organizations that are part of the intervention. Within an organization, certain disciplines or units may be more involved than others, and some may not be involved (e.g., nursing leadership, hospitalists, emergency department). External organizations and networks may be categorized as belonging to the outer setting but nonetheless involve accountability in order for the intervention to succeed.
  ○ Continuity was added to emphasize the importance of exchange of information and relationships between organizations and with patients/caregivers.
- Characteristics and Roles of Providers: “Roles” was added to this domain to emphasize the importance of provider roles in care transition interventions. For parsimony, characteristics of providers, patients, and caregivers are combined in the table but remain separate in the graphic to emphasize their unique contributions.
- Characteristics and Roles of Patients and Caregivers: Technical Expert Panel members agreed patients should be emphasized in the framework; moreover, caregivers have roles and needs unique from those of patients. We created two new constructs, patient needs and resources and caregiver needs and resources, to emphasize this distinction.
- Process of Implementation: This domain had a number of notable construct modifications and additions.
  ○ Physical space was adapted to also include presence of organizations, as the physical presence of providers/facilitators from other organizations may be key to building and sustaining collaborations.
  ○ Engaging organizations, external context was added to highlight the significance of the external context in care transitions.
  ○ Practice roles was renamed transition roles to enhance its resonance to care transitions researchers and evaluators.
  ○ Integrators was added as a subconstruct under transition roles. Integrators are responsible for building relationships/collaborations between organizations; their role is central to many sponsored care transitions programs, such as Better Outcomes for Older Adults through Safe Transitions (BOOST).
  ○ Measurement capability and data availability was added as a subconstruct of reflecting and evaluating. Lack of data or of quality data often leads to failure of the project. Common issues go beyond barriers related to information technology and include measurement differences between organizations; lack of availability or sharing; accountability for collection, documentation, and analysis; and timeliness.
- Measures of Implementation: The construct of evolvability was added to reflect description of adaptations made to the intervention components and how these were implemented. The construct reach was further broken down into reach within the population and reach within the organization, as the intervention may aim to do one but not the other, or both.
- Outcomes: There was no consensus on what patient-centered outcomes should be included and whether adverse drug outcomes should be considered patient centered or clinical. We chose to maintain the outcomes developed for the PCMH Framework, as they aligned well to the outcomes for care transitions. The only change was to redefine patient-centered outcomes to include caregivers, and to emphasize achievement of goals and care consistent with preferences.

## Graphic Representation of the Care Transitions Framework

Figure 6 is a graphic representation of the Care Transitions Framework. Although all Technical Expert Panel members agreed that patient-centeredness is the ideal, they had different perspectives on whether the graphic should have patients and caregivers at the center. Some argued that intervention design is usually centered around organizations, based on issues such as policies, payment, speed, funding, and research opportunities, and that organizations are the leaders of this work; institutional outcomes such as readmissions and cost, rather than patient-centered outcomes such as quality of life, are usually the primary goal. For others, the primary reason for the intervention is the patient, and if the intervention cannot be personalized to heterogeneous patient and caregiver needs, it will not be effective. We addressed these comments by creating two distinct areas within the graphic for providers and patients.

Figure 6 Framework for Implementation Research on Care Transitions

Figure 6 is a graphic representing the relationship between the domains of the Care Transitions Framework. On the left side of the graphic, the following five domains are shown as equal parts of a circle: intervention characteristics, organizational characteristics, characteristics and roles of providers, characteristics and roles of patients and caregivers, and process of implementation. This circle is surrounded by another circle that represents the external context domain. These two concentric circles feed into an arrow-shaped box to the right labeled Measures of Implementation. The Measures of Implementation box feeds into an arrow-shaped box on the far right of the figure called Outcomes.

On the left side of the figure, the five domains of care transition interventions are shown in a circle that includes the attributes of the intervention itself, and the individuals and organizations or systems carrying out the intervention or the target of the intervention. These domains are Intervention Characteristics, Organizational Characteristics, Characteristics & Roles of Providers, Characteristics & Roles of Patients and Caregivers, and Process of Implementation. The outer ring of the circle represents the External Context, outside the domains of intervention, organizations, individuals, and process. An arrow to the right of the circle points to the Measures of Implementation, which influence Outcomes.

## How To Use the Care Transitions Framework

The nature of care transitions interventions is such that details of development and implementation vary from one context to another, depending on a variety of issues. Therefore, the framework does not prescribe a set of domains or constructs that must be considered during evaluation; rather it provides a comprehensive, though not exhaustive, set of potential items that teams working on care transitions interventions research can choose, depending on the nature of the research or evaluation goals and questions.

The following flowchart (Figure 7) presents step-by-step guidance on how this framework can be used. The flowchart presents a series of questions, and each set of questions is tied to a particular domain in the framework (Tables 18 through 24). As these questions are considered, the user should refer to the appropriate domain in the framework table to see which constructs are relevant. For example, Step 1 corresponds to the Intervention Characteristics domain; as the team considers the various issues related to this domain, they should refer to the framework to choose those constructs relevant to them. In particular, in many interventions, the discharging or receiving setting will have little control or relationship with the other setting, as well as little control over the external context. Ideally, interventions would try to create these relationships or links between settings. While following this step-by-step process of using the framework, we recommend that users of the framework select qualities, features, or characteristics that are closely tied to intervention outcomes such as utilization (e.g., readmissions, completion of followup tests) and patient satisfaction with the discharge process (see Outcomes domain in Table 24). Furthermore, the user is advised to use the goals, research questions, and theories guiding the investigation to prioritize the constructs for inclusion. Doing so will ensure the investigation remains focused on its essential purpose and keep the number of constructs to a manageable size.

Figure 7 How to Use the Care Transitions Framework

Figure 7 is a flowchart with eight steps that correspond to the eight domains in the Care Transitions Framework. The eight steps are aligned vertically in boxes, starting with step 1 at the top of the figure and ending with step 8 at the bottom of the figure. Each step has an arrow pointing down to the next step. The first step in the flowchart is to define the intervention. The second step is to define the external context. The third step is to define the organizational characteristics. The fourth step is to define the characteristics and roles of providers. The fifth step is to define the characteristics and roles of patients and caregivers. The sixth step is to define the process of implementation. The seventh step is to define the measures of implementation. The eight and final step is to define the outcomes. The right-hand side of each step includes a series of questions for users to consider in completing the step.

## Content of the Care Transitions Framework

In Tables 18 through 24, we present the Care Transitions Framework with brief definitions of the constructs, subconstructs, and examples. Constructs added to the CFIR are labeled as “New,” and many other constructs are adapted to better fit with care transitions; a few are named differently or included or excluded here based on differences from the PR or PCMH Frameworks, but most are similar. We added clarifying examples for those constructs and subconstructs that were unclear or complex. Each construct or subconstruct is independent and should be applied as appropriate to the research questions and objectives. Please note, as well, that because the constructs for provider, patient, and caregiver characteristics and roles are identical, we have combined them into a single section of the table to maintain parsimony. They remain separate in the graphic to highlight their distinctiveness.

## Applying the Care Transitions Framework: A Case Study

Below is an adapted version of a case study from the Robert Wood Johnson Foundation's Aligning Forces for Quality program.32 We use this modified example to illustrate how the Care Transitions Framework may be used.

### Reducing Readmissions and Integrating Care in Cincinnati

The Health Improvement Collaborative of Greater Cincinnati Alliance (the Collaborative), sponsored by the Robert Wood Johnson Foundation Aligning Forces for Care Quality (AF4Q), was established to improve communication and coordination among hospitals and physician groups. The Collaborative) partnered with the local hospital association and the Greater Cincinnati Health Council to reduce heart failure readmissions by 10 percent under a program called Accountable Care Transformation, or ACT.

Nineteen hospitals and health systems participate in ACT and promote five best practices to reduce readmissions—

1. Upon admission, implement a risk-assessment tool with a focus on heart failure to identify patients who are at high risk of readmission from social factors.
2. Use the teach-back method during the hospital stay from admission to discharge during key clinical interventions.
3. Provide real-time handover communications.
4. Address timely physician followup (appointment to occur within 5 to 7 days of discharge).
5. Follow up with the patient or primary caregiver (or emergency contact) within 48 to 72 hours of discharge via telephone or home visit.

The five practices draw from a variety of sources, including Project Better Outcomes for Older adults through Safe Transitions (BOOST), the STAAR Initiative, and the Institute for Healthcare Improvement. The ACT rests on two core principles: collaboration and transparency. The Collaborative is regional because patients cross routinely from one community within the Cincinnati region to another. It is not bound by hospital structures; even within a competitive environment, hospitals have to share data and communicate with one another in order to adhere to the five practices.

According to the medical director of the Collaborative, implementation and evaluation have been challenging. The Collaborative is not receiving data in real time, which creates delays in the implementation timeline. This lag in data submission also has hampered the Collaborative's ability to track dollars saved and number of readmissions reduced; however, self-reported data from hospitals participating in the ACT indicate a downward trend in readmissions. The medical director added, “But regardless of whether we meet our goal, the journey and the process has been so helpful and has improved care for patients in our communities.”

### Applying the Care Transitions Framework

Below, we apply the flowchart to the case study, selecting a few constructs as examples for each step.

#### Step 1 Define the Intervention Characteristics

- What is the intervention designed to achieve?
  The goal of this intervention is to reduce heart failure readmissions. In a broader sense, the intervention is building a collaborative and working to coordinate care across disparate organizations.
- What are the features of the intervention?
  The intervention for this case has five key elements, all adapted from established care transitions programs but rebundled for this collaborative:
  1. Implement a heart failure readmission risk assessment tool.
  2. Use the teach-back method during key clinical interventions.
  3. Provide real-time handover communications.
  4. Address timely physician followup.
  5. Follow up with the patient or primary caregiver after discharge.
  Relevant constructs may include feasibility (e.g., whether all these elements can realistically be carried out at all hospitals, including issues of cost-effectiveness), complexity (e.g., difficulty of implementing five disparate elements of the intervention, which will require involvement of a number of providers, including training), and the workflows and task/process standardization that will be needed to incorporate tasks such as teach-back into daily care. See Table 18.
- Who is the intended target group?
  The ultimate beneficiary of the changes in practices is the patient, who is thus a primary stakeholder. However, much of the intervention is focused on changes in processes and workflows within and between hospitals, so other targeted entities include providers and staff, units, and hospitals. See Table 18.

#### Step 2 Define the External Context

- What components of the environment will impact the implementation?
  Key constructs for external context may include external networks, or existing relationships with outpatient providers who will need to see the patient in a timely way to achieve timely physician followup (element #4), and the external pressure and policy incentives to reduce heart failure readmissions. See Table 19.

#### Step 3 Define the Organizations Involved and Their Characteristics

- Which organizations are directly involved in the intervention?
  For this case, the 19 hospitals and health systems are included, as well as community and national organizations: the Health Improvement Collaborative of Greater Cincinnati, Greater Cincinnati Health Council (hospital organization), and the Robert Wood Johnson Foundation.
- Which components of structure and process within and between these organizations will impact the implementation?
  Key structural characteristics may include the size and organizational resources of the various 19 hospitals, which could influence their capacity, internal support, and ability to be flexible enough to make the multiple changes needed. The implementation climate could affect how willing the individual organizations are to change care processes to improve care transitions. Other important constructs include individual organizational accountability for reducing heart failure readmissions in the larger collaborative, relative priority within the organizations to dedicate to the elements of the intervention as compared to other priorities, and leadership engagement to support the organizations and staff in implementing the intervention. See Table 20.

#### Step 4 Define the Characteristics and Roles of the Providers

- What are the characteristics of individuals who are engaged in the provision of care or treatment?
  For this intervention, provider roles may be particularly important, as new roles (especially discharge followup) need to be developed within each organization. Collective efficacy, belief that the intervention can be achieved, is needed at the individual and organizational as well as the collaborative level. See Table 21.

#### Step 5 Define the Characteristics and Roles of Patients and Caregivers

- What are the characteristics and roles of patients and caregivers that will impact their ability to engage in the intervention or to benefit from it?
  The importance of patient goals, needs, preferences, and resources is reflected in the first element of the intervention—risk assessment for readmission, including social factors—and these factors may affect the implementation of the intervention and readmission outcomes. Knowledge and beliefs and skills and competencies are important for the effectiveness of the teach-back method and phone followup, and social factors such as access to transportation and a telephone could affect physician followup. See Table 21.

#### Step 6 Define the Processes Required To Achieve Desired Level of Use

- What are the implementation processes applied to achieve individual- and organizational-level use of the intervention?
  For this case, planning is important, with the elements of the intervention chosen from existing programs and rebundled for this collaborative. Engaging patients and caregivers and providers is also critical, with important information exchange in teach-back and postdischarge phone calls for patients/caregivers, and effective handoff communication with providers. Measurement capability and data availability are particularly important for care transitions interventions; in this case, outcomes could not be evaluated due to issues with accessing data from the various organizations involved. See Table 22. This step does not cover how completely an intervention was used; this concept is covered under the Measures of Implementation domain.

#### Step 7 Define Measures of Implementation

- What are the attributes of the implementation process that should be measured to determine how it was carried out and can be sustained?
  In care transitions interventions, specific elements may not be implemented as planned, or may require adjustment during implementation or after initial evaluation. Evaluating what was actually implemented and the measures of implementation is critical to understanding the intervention and outcomes. Potentially useful aspects to be measured reflect many of the constructs described above, including acceptability of the intervention among stakeholders and the fidelity to the established protocol and design within each organization. Reach within the organization would examine the providers involved in care of the patients, while reach within the population would examine patients and caregivers. Better measurement of the implementation process might help to identify barriers as well as solutions effective in some organizations that could be helpful to others. See Table 23.

#### Step 8 Define the Outcomes

- What are the specific, measurable outcomes that will result from the intervention?
  In this case, the focus was on readmissions as an outcome of health care utilization, but many other possible outcomes could have been relevant, including those focused on patients and caregivers, such as achieving patient- and caregiver-centered outcomes, the patient/caregiver experience of care; cost effects/impact; and unintended consequences (e.g., the burden of the substantial investment required for followup postdischarge). See Table 24.