# Technical Expert Panel Composition, Methods, and Input on Usability

## Process Redesign and Patient-Centered Medical Home Technical Expert Panels

Table C-1 shows the distribution of expertise in each TEP. The PCMH TEP included 7 members, and the PR TEP included 8 members (2 individuals served on both TEPs).

Table C-1 Representation on the Process Redesign and Patient-Centered Medical Home Technical Expert Panels

PCMH TEP Member | Research and Evaluation | Management and Practice | General Implementation Research Expertise | Served on Both TEPs
1 | — | — | X | X
2 | X | X | — | —
3 | X | — | — | —
4 | X | X | — | —
5 | X | X | — | —
6 | — | — | X | X
7 | X | — | — | —
PR TEP Member | Research and Evaluation | Management and Practice | General Implementation Research Expertise | Served on Both TEPs
1 | — | — | X | X
2 | X | — | — | —
3 | X | — | — | —
4 | X | — | — | —
5 | X | — | — | —
6 | — | X | — | —
7 | X | — | — | —
8 | — | — | X | X

Abbreviations: PCMH = Patient-Centered Medical Home; PR = process redesign; TEP = Technical Expert Panel.

To prepare the TEP for the first discussion, we sent the draft contextual frameworks a week in advance for the members to review. During the first call, a member of the team that developed the CFIR oriented the TEPs to the CFIR and answered their questions. Using the feedback from the initial discussion, we made modifications to the draft frameworks and reviewed these with the TEP on the second call. In addition, we asked the TEP to provide feedback on a set of multilevel analyses tables we created to accompany the frameworks. These tables were intended to help the user apply the constructs in the framework to multiple levels of analysis.

We used the following set of questions to elicit feedback to guide the adaptation of the CFIR:

- Is the CFIR in its original form an appropriate guide for the study of PCMH/PR implementation?
- What are the most important changes that need to be made to the CFIR?
- What are the most important constructs for PCMH/PR implementation research?
- Are some CFIR constructs related to adoption vs. implementation; are adoption constructs appropriate for an implementation framework?
- Are there entire domains or specific “variables” where we need to take into account change during the life course of an intervention/system change?
- Could one level of analysis be chosen as the focal level for a given study, with the others then seen as interacting with the focal level?
- Should “implementation outcomes” (Proctor et al.1) and final outcomes be included in the framework?
- Is there a manageable way of addressing the way context and the intervention interact and co-evolve?

## Care Transitions Technical Expert Panel

Similar to the composition of TEPs for PCMH and PR earlier, we aimed to include individuals with diverse professional perspectives for the Care Transitions TEP encompassing research and evaluation, health care providers, and those engaged in developing and implementing Care Transitions interventions. The Care Transitions TEP included 11 members. Table C-2 shows the distribution of perspectives among the TEP.

Table C-2 Representation on the Care Transitions Technical Expert Panel

— | Perspective
TEP Member | Provider/Researcher | Association
1 | — | X
2 | X | —
3 | X | X
4 | — | X
5 | X | —
6 | — | X
7 | X | —
8 | X | —
9 | — | X
Co10 | X | —
11 | — | X

Abbreviations: TEP = Technical Expert Panel.

Using a similar protocol to the PCMH and PR TEPs, materials were sent to the Care Transitions TEP to review 1 week in advance of the first call. During the first call, a senior member of the investigative team gave a brief presentation on the CFIR. The orientation to the CFIR was followed by a structured discussion focused on the applicability of the draft Care Transitions Framework with the goal of addressing several overarching questions:

- Is the CFIR in its adapted form an appropriate guide for Care Transitions implementation research?
- Are the domains and constructs of the CFIR adapted appropriately for Care Transitions implementation research?
- What modifications are needed to the draft graphic (Care Transitions Framework) to provide a useful and accurate representation of Care Transitions implementation research?
- What important aspects of Care Transitions implementation research are missing from the constructs in the framework?
- How should the Care Transitions Framework frame issues of patient- or caregiver-centered care (including the key area of patient and family engagement)?
- How should links or integration between the settings for Care Transitions best be used to adapt the CFIR?
- How can the adapted CFIR best represent the concept of accountability or the home of coordination (that can rest in either or both settings)?

Based on the results of these TEP calls, we summarized input on the adaptation of the framework and developed a set of recommendations and questions for additional clarification in the second set of calls. The following questions were the focus of this second set of calls:

- Does the framework help you as a researcher identify and define the core components of the intervention?
- Does making a distinction between Inner (Core) Settings and Outer Context help you define the intervention?
- How can the framework best represent the concepts of accountability and coordination at the patient level?
- How can the framework best represent the concept of collaboration at the organizational level?
- What important aspects of Care Transitions implementation research are missing from the constructs in the framework?
- Are the domains and constructs of the framework adapted appropriately for Care Transitions implementation research?
- How should the framework frame issues of patient- or caregiver-centered care?

We also developed two case studies to evaluate the utility of the framework for designing the evaluation or a study of a typical Care Transitions intervention. The subject of the first case study was the Health Improvement Collaborative of Greater Cincinnati; the second case study featured the transition of a fictional patient named “Mrs. Davis” from hospital to home. These cases were drawn from a policy brief of the Aligning Forces for Quality Initiative.2

## Usability Technical Expert Panel

In a second phase of this project, the team evaluated the usability of the PCMH and PR Frameworks by convening two new TEPs, one to assess each framework. The PCMH TEP consisted of 6 members, and the PR TEP had 5 members. Table C-3 shows the distribution of perspectives in each TEP.

Table C-3 Representation on the patient-centered medical home and process redesign usability Technical Expert Panels

PCMH Usability TEP Member | Researcher | Health Care Executive and/or Provider
1 | X | —
2 | X | —
3 | X | —
4 | X | X
5 | X | —
6 | X | —
PR Usability TEP Member | Researcher | Health Care Executive and/or Provider
1 | X | —
2 | X | —
3 | X | —
4 | | X
5 | X | —

Abbreviations: PCMH = Patient-Centered Medical Home; PR = process redesign; TEP = Technical Expert Panel.

Each TEP met twice. During these TEP calls, members discussed the effectiveness and ease of use of the PCMH and PR Frameworks. Effectiveness discussions focused on the following questions:

- How useful is the PCMH Framework (or PR Framework) for implementation research?
- Does the framework meet the following criteria?3
  ○ Familiarity
  ○ Resonance
  ○ Parsimony
  ○ Coherence
  ○ Differentiation

Ease of use discussions centered on the following questions:

- How can the structure and organization of the PCMH Framework (or PR Framework) be improved to enhance ease of use?
- What the pros and cons of various formats for viewing the framework (hardcopy, online, etc.) and which formats are preferred?

We followed up this TEP call with a second set of TEP calls where we provided experts with two case studies, and asked them to share their experiences while applying the PCMH or PR Frameworks to these case studies. The PCMH TEP received two case studies of PCMH implementation initiatives: the first in a pediatric practice in Saginaw, Michigan,4 and the second in an integrated provider network in Seattle, Washington.5 The PR TEP also received two case studies: a productivity improvement activity carried out by a hospital-owned physician practice6 and a lean implementation in a large federally qualified health center in California.7 The following questions guided our case study discussions.

- What contextual factors are important to this case study?
- Does the PCMH Framework (or PR Framework) contain all the relevant contextual factors needed to evaluate the outcomes of interest? Are any factors missing?
- What were the challenges you encountered while applying the PCMH Framework (or PR Framework) to this case study?
- Considering the contextual factors you selected for each study:
  ○ At what levels of analysis (e.g., individual, family, team, organization, and system) should these contextual factors be measured?
  ○ How might these contextual factors change over time?
  ○ At what stage of research might these contextual factors be less or more important?
  ○ Should anything be added to the framework that would help the researcher think through these issues?
- Did the structure and format of the adapted PCMH Framework (or PR Framework) make it easy for you to search for domains and constructs? Do you have any suggestions to improve the structure and format?
- How would you have approached the research design question if you had not been asked to use the modified CFIR? Did the addition of the framework add value to your design?

## Input on Usability

The Self-Assessment and the Usability TEP conferences together provided rich information that allowed the project team to assess the processes and materials used in developing the initial PR and PCMH Frameworks. As we compiled the various recommendations for the frameworks, a few stood out as being repeated in various scenarios regarding both the PCMH and PR Frameworks (e.g., during multiple TEP calls, as a major discussion point during one TEP call, during a TEP call, and through the document review). In Table C-4, we present these recommendations. They represent solutions to some of the more frequently encountered challenges to using the framework and heavily influenced the methods for adaptation of CFIR to Care Transitions. The frameworks contained in this document are the refined versions, and already include a majority of the changes suggested below.

Table C-4 Major recommendations to update the Patient-Centered Medical Home and Process Redesign Frameworks

- The purpose of the frameworks and intended target group is not clear and needs to be provided.; - The various tables in the frameworks documents need modifications. The main construct table may be made clearer by reducing lengthy descriptions, streamlining the level of analysis, clarifying ambiguous terms, and adding brief examples. The multilevel analysis table and the stages of implementation table are not clear in their current form and require accompanying text to clarify their purpose.; - The graphical representation is extremely useful, and needs to be expanded and moved ahead of the framework table.; - A roadmap or how-to-use guide is necessary for new users to understand the purpose of the framework and steps to use it effectively. A case study may also be added to the framework document as part of this how-to-use guide.; - Regarding format of the frameworks, an interactive online format, with the ability to read and print from a PDF document, would be most useful because it would provide multiple modes of interaction for users. In addition, small usability-related changes to the document (such as color coding domains) can help make the framework easier to read and understand.

Abbreviations: PCMH = Patient-Centered Medical Homes; PR = process redesign.

## References

1 Proctor E, Silmere H, Raghavan R, et al. Outcomes for implementation research: conceptual distinctions, measurement challenges, and research agenda. Adm Policy Ment Health. Mar. 2011;38(2):65-76. [pmid: 20957426].
2 Robert Wood Johnson Foundation. Care across settings: challenges, successes and opportunities. 2013. www.rwjf.org/content/dam/farm/reports/issue_briefs/2013/rwjf404875. June 11 2013.
3 Gerring J. What makes a concept good? A critical framework for understanding concept formation in the social sciences. Polity. Spring. 1999;31(3):357-93.
4 Michigan State Medical Society. Innovation in Physician Practices: 13 Case Studies to Guide Michigan Physicians. 2011. www.msms.org/AM/Template.cfm?Section=Your_Practice&TEMPLATE=/CM/ContentDisplay.cfm&CONTENTID=17061. June 11, 2013.
5 Hsu C, Coleman K, Ross TR, et al. Spreading a patient-centered medical home redesign: a case study. J Ambul Care Manage. Apr-Jun. 2012;35(2):99-108. [pmid: 22415283].
6 McCarthy EL. Physician office productivity improvement through operations analysis and process redesign. J Ambul Care Manage. Oct. 2002;25(4):37-52. [pmid: 12371018].
7 Stephens J, Carman K, Smeeding L, et al. Implementing Lean in a safety-net clinic: a case study summary. American Institutes for Research. 2012. www.chcf.org/∼/media/MEDIA%20LIBRARY%20Files/PDF/I/PDF%20ImplementingLeanSafetyNetSummary.pdf. June 11, 2013.