# Included Articles From Literature Scans

## Process Redesign and Patient-Centered Medical Home Literature

1 Alexander JA, Hearld LR. The science of quality improvement implementation: developing capacity to make a difference. Med Care. Dec. 2011;49(Suppl):S6-20. [pmid: 20829724].
2 Arora VM, Johnson JK, Meltzer DO, et al. A theoretical framework and competency-based approach to improving handoffs. Qual Saf Health Care. Feb. 2008;17(1):11-4. [pmid: 18245213].
3 Ben-Tovim DI, Bassham JE, Bennett DM, et al. Redesigning care at the Flinders Medical Centre: clinical process redesign using “lean thinking”. Med J Aust. Mar. 17. 2008;188(6 Suppl):S27-31. [pmid: 18341473].
4 Bray P, Roupe M, Young S, et al. Feasibility and effectiveness of system redesign for diabetes care management in rural areas: the eastern North Carolina experience. Diabetes Educ. Sep-Oct. 2005;(5):712-8. [pmid: 16203855].
5 Burston S, Chaboyer W, Wallis M, et al. A discussion of approaches to transforming care: contemporary strategies to improve patient safety. J Adv Nurs. Nov. 2011;67(11):2488-95. [pmid: 21627678].
6 Carayon P, Schoofs Hundt A, Karsh BT, et al. Work system design for patient safety: the SEIPS model. Qual Saf Health Care. Dec. Suppl 1. 2006;15:i50-8. [pmid: 17142610].
7 Damschroder L, Aron D, Keith R, et al. Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implementation Science. 2009;4(1):50. PMID:. [doi: 10.1186/1748-5908-4-50]. [pmid: 19664226].
8 Duckers ML, Wagner C, Vos L, et al. Understanding organisational development, sustainability, and diffusion of innovations within hospitals participating in a multilevel quality collaborative. Implement Sci. 2011;6:18. [pmid: 21385467].
9 Feeley TW, Fly HS, Albright H, et al. A method for defining value in healthcare using cancer care as a model. J Healthc Manag. Nov-Dec. 2010;55(6):399-411. discussion -2. [pmid: 21166323].
10 Feldstein AC, Glasgow RE. A practical, robust implementation and sustainability model (PRISM) for integrating research findings into practice. Jt Comm J Qual Patient Saf. Apr. 2008;34(4):228-43. [pmid: 18468362].
11 Franx G, Oud M, De Lange J, et al. Implementing a stepped care approach in primary care. Results of a qualitative study. Implement Sci. Jan. 31. 2012;7(1):8. [pmid: 22293362].
12 Glasgow RE, Dickinson P, Fisher L, et al. Use of RE-AIM to develop a multi-media facilitation tool for the patient-centered medical home. Implement Sci. 2011;6:118. [pmid: 22017791].
13 Harrison MI, Kimani J. Building capacity for a transformation initiative: system redesign at Denver Health. Health Care Manage Rev. Jan-Mar. 2009;34(1):42-53. [pmid: 19104263].
14 Harwood L, Ridley J, Lawrence-Murphy JA, et al. Nurses' perceptions of the impact of a renal nursing professional practice model on nursing outcomes, characteristics of practice environments and empowerment--Part I. CANNT J. Jan-Mar. 2007;17(1):22-9. [pmid: 17405392].
15 Helfrich CD, Li YF, Sharp ND, et al. Organizational readiness to change assessment (ORCA): development of an instrument based on the Promoting Action on Research in Health Services (PARIHS) framework. Implement Sci. 2009;4:38. [pmid: 19594942].
16 Henriksen K, Joseph A, Zayas-Caban T. The human factors of home health care: a conceptual model for examining safety and quality concerns. J Patient Saf. Dec. 2009;5(4):229-36. [pmid: 22130216].
17 Holden RJ. Lean Thinking in emergency departments: a critical review. Ann Emerg Med. Mar. 2011;57(3):265-78. [pmid: 21035904].
18 Jasovsky DA, Morrow MR, Clementi PS, et al. Theories in action and how nursing practice changed. Nurs Sci Q. Jan. 2010;23(1):29-38. [pmid: 20026725].
19 Kaplan HC, Provost LP, Froehle CM, et al. The Model for Understanding Success in Quality (MUSIQ): building a theory of context in healthcare quality improvement. BMJ Qual Saf. Jan. 2012;21(1):13-20. [pmid: 21835762].
20 King HB, Battles J, Baker DP, et al. TeamSTEPPS™: Team Strategies and Tools to Enhance Performance and Patient Safety. Rockville, MD. 2008.
21 Kirsh S, Watts S, Pascuzzi K, et al. Shared medical appointments based on the chronic care model: a quality improvement project to address the challenges of patients with diabetes with high cardiovascular risk. Qual Saf Health Care. Oct. 2007;16(5):349-53. [pmid: 17913775].
22 Kirsh SR, Lawrence RH, Aron DC. Tailoring an intervention to the context and system redesign related to the intervention: a case study of implementing shared medical appointments for diabetes. Implement Sci. 2008;3:34. [pmid: 18533021].
23 Kochevar LK, Yano EM. Understanding health care organization needs and context. Beyond performance gaps. J Gen Intern Med. Feb. Suppl 2. 2006;21:S25-9. [pmid: 16637957].
24 Lanham HJ, McDaniel RR Jr., Crabtree BF, et al. How improving practice relationships among clinicians and nonclinicians can improve quality in primary care. Jt Comm J Qual Patient Saf. Sep. 2009;35(9):457-66. [pmid: 19769206].
25 Lemmens KM, Nieboer AP, van Schayck CP, et al. A model to evaluate quality and effectiveness of disease management. Qual Saf Health Care. Dec. 2008;17(6):447-53. [pmid: 19064661].
26 Luck J, Hagigi F, Parker LE, et al. A social marketing approach to implementing evidence-based practice in VHA QUERI: the TIDES depression collaborative care model. Implement Sci. 2009;4:64. [pmid: 19785754].
27 Martin CM. Chronic disease and illness care: adding principles of family medicine to address ongoing health system redesign. Can Fam Physician. Dec. 2007;53(12):2086-91. [pmid: 18077734].
28 Murray E, Burns J, May C, et al. Why is it difficult to implement e-health initiatives? A qualitative study. Implement Sci. 2011;6:6. [pmid: 21244714].
29 Ovretveit J, Scott T, Rundall TG, et al. Improving quality through effective implementation of information technology in healthcare. Int J Qual Health Care. Oct. 2007;19(5):259-66. [pmid: 17717038].
30 Peikes D, Zutshi A, Genevro J, et al. Early Evidence on the Patient-Centered Medical Home Final Report. (Prepared by Mathematica Policy Research, under Contract Nos. HHSA290200900019I/HHSA29032002T and HHSA290200900019I/HHSA29032005T). Rockville, MD. Agency for Healthcare Research and Quality. February. 2012.
31 Post EP, Kilbourne AM, Bremer RW, et al. Organizational factors and depression management in community-based primary care settings. Implement Sci. 2009;4:84. [pmid: 20043838].
32 Profit J, Typpo KV, Hysong SJ, et al. Improving benchmarking by using an explicit framework for the development of composite indicators: an example using pediatric quality of care. Implement Sci. 2010;5:13. [pmid: 20181129].
33 Rippen HE, Pan EC, Russell C, et al. Organizational framework for health information technology. Int J Med Inform. 2012. Feb. 27. [pmid: 22377094].
34 Siminerio LM. The role of technology and the chronic care model. J Diabetes Sci Technol. Mar. 2010;4(2):470-5. [pmid: 20307409].
35 Singh R, Singh A, Fox C, et al. Computer visualisation of patient safety in primary care: a systems approach adapted from management science and engineering. Inform Prim Care. 2005;13(2):135-44. [pmid: 15992498].
36 Vest JR, Gamm LD. A critical review of the research literature on Six Sigma, Lean and StuderGroup's Hardwiring Excellence in the United States: the need to demonstrate and communicate the effectiveness of transformation strategies in healthcare. Implement Sci. 2009;4:35. [pmid: 19570218].
37 Walsh K, Antony J. An assessment of quality costs within electronic adverse incident reporting and recording systems: a case study. Int J Health Care Qual Assur. 2009;22(3):203-20. [pmid: 19537183].

## Care Transitions Literature

1 Transitions of Care Measures. National Transitions of Care Coalition. http://www.ntocc.org/Portals/0/PDF/Resources/TransitionsOfCare_Measures.pdf. February 8, 2013.
2 Care Transitions Performance Measurement Set. AMA. 2009. www.ama-assn.org/ama/pub/physician-resources/physician-consortium-performance-improvement.page. February 8, 2013.
3 Allen KR, Hazelett SE, Jarjoura D, et al. The after discharge care management of low income frail elderly (AD-LIFE) randomized trial: theoretical framework and study design. Popul Health Manag. Jun. 2011;14(3):137-42. [pmid: 21323461].
4 Almaden S, Freshman B, Quaye B. Case management redesign in an urban facility. Prof Case Manag. Jul-Aug. 2011;16(4):199-209. [pmid: 21646895].
5 Babcock CW, Robinson LE. A novel approach to hospital palliative care: an expanded role for counselors. J Palliat Med. Apr. 2011;14(4):491-500. [pmid: 21410337].
6 Coleman EA, Parry C, Chalmers S, et al. The care transitions intervention: results of a randomized controlled trial. Arch Intern Med. Sep. 25. 2006;166(17):1822-8. [pmid: 17000937].
7 Geary CR, Schumacher KL. Care transitions: integrating transition theory and complexity science concepts. ANS Adv Nurs Sci. Jul. 2012;35(3):236-48. [pmid: 22869210].
8 Graham CL, Ivey SL, Neuhauser L. From hospital to home: assessing the transitional care needs of vulnerable seniors. Gerontologist. Feb. 2009;49(1):23-33. [pmid: 19363001].
9 Holland DE, Harris MR. Discharge planning, transitional care, coordination of care, and continuity of care: clarifying concepts and terms from the hospital perspective. Home Health Care Serv Q. 2007;26(4):3-19. [pmid: 18032197].
10 Manser T, Foster S, Gisin S, et al. Assessing the quality of patient handoffs at care transitions. Qual Saf Health Care. Dec. 2010;19(6):e44. [pmid: 21127094].
11 McCarthy D, Cohen A, Johnson M. Case study series synthesis: Innovations in care transitions. Gaining ground: Care management programs to reduce hospital admissions and readmissions among chronically ill and vulnerable patients. The Commonwealth Fund. 2013. http://www.commonwealthfund.org/Publications/Case-Studies/2013/Jan/Care-Transitions-Synthesis.aspx. February 8, 2013.
12 Moore C, McGinn T, Halm E. Tying up loose ends: discharging patients with unresolved medical issues. Arch Intern Med. Jun. 25. 2007;167(12):1305-11. [pmid: 17592105].
13 Naylor M. Transitional care conceptual model. Transitional Care Model. www.transitionalcare.info. February 8, 2013.
14 Naylor MD. Transitional care: a critical dimension of the home healthcare quality agenda. J Healthc Qual. Jan-Feb. 2006;28(1):48-54. [pmid: 16681300].
15 Naylor MD, Sochalski JA. Scaling up: bringing the transitional care model into the mainstream. Issue Brief (Commonw Fund). Nov. 2010;103:1-12. [pmid: 21053533].
16 Prvu Bettger J, Alexander KP, Dolor RJ, et al. Transitional care after hospitalization for acute stroke or myocardial infarction: a systematic review. Ann Intern Med. Sep. 18. 2012;157(6):407-16. [pmid: 22986378].
17 Rennke S, Shoeb M, Nguyen O, et al. Interventions to Improve Care Transitions at Hospital Discharge. AHRQ. 2013. http://www.ahrq.gov/research/primarix.htm. February 8, 2013.
18 Snow V, Beck D, Budnitz T, et al. Transitions of Care Consensus Policy Statement American College of Physicians-Society of General Internal Medicine-Society of Hospital Medicine-American Geriatrics Society-American College of Emergency Physicians-Society of Academic Emergency Medicine. J Gen Intern Med. Aug. 2009;24(8):971-6. [pmid: 19343456].
19 Wong FK, Chan MF, Chow S, et al. What accounts for hospital readmission?. J Clin Nurs. Dec. 2010;19(23-24):3334-46. [pmid: 21029227].