# References

1 Finding what works in healthcare. Standards for systematic reviews. Washington, DC. Institute of Medicine of the National Academies. 2011.
2 Chandler J, Churchill R, Higgins J, et al. Methodological standards for the conduct of new Cochrane intervention reviews. 2011. www.editorial-unit.cochrane.org/mecir.
3 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. Journal of clinical epidemiology. 2011;64(11):1187-1197. [pmid: 21477993].
4 Trikalinos TA, Balion CM, Coleman CI, et al. Chapter 8: meta-analysis of test performance when there is a “gold standard”. Journal of general internal medicine. Suppl 1. 2012;27(S56-66). [pmid: 22648676].
5 Light RJ, Pillemer DB. Summing up: The science of reviewing research. Cambridge, MA. Harvard University Press. 1984.
6 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA : the journal of the American Medical Association. 2000;283(15):2008-2012. [pmid: 10789670].
7 Lau J, Ioannidis JP, Terrin N, et al. The case of the misleading funnel plot. BMJ. 2006;333(7568):597-600. [pmid: 16974018].
8 Terrin N, Schmid CH, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. Journal of clinical epidemiology. 2005;58(9):894-901. [pmid: 16085192].
9 Terrin N, Schmid CH, Lau J, et al. Adjusting for publication bias in the presence of heterogeneity. Statistics in medicine. 2003;22(13):2113-2126. [pmid: 12820277].
10 Sterne JA, Gavaghan D, Egger M. Publication and related bias in meta-analysis: power of statistical tests and prevalence in the literature. Journal of clinical epidemiology. 2000;53(11):1119-1129. [pmid: 11106885].
11 Deeks JJ, Macaskill P, Irwig L. The performance of tests of publication bias and other sample size effects in systematic reviews of diagnostic test accuracy was assessed. Journal of clinical epidemiology. 2005;58(9):882-893. [pmid: 16085191].
12 Dahabreh IJ, Chung M, Kitsios GD, et al. Comprehensive Overview of Methods and Reporting of Meta-Analyses of Test Accuracy. Agency for Healthcare Research and Quality (US). 2012;22553887. PMID: N/A.
13 Juni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA : the journal of the American Medical Association. 1999;282(11):1054-1060. [pmid: 10493204].
14 Greenland S. Invited commentary: a critical look at some popular meta-analytic methods. American journal of epidemiology. 1994;140(3):290-296. [pmid: 8030632].
15 Greenland S. Quality scores are useless and potentially misleading. American journal of epidemiology. 1994;140(3):301-302. [pmid: 8030632].
16 Bradburn MJ, Deeks JJ, Berlin JA, et al. Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Statistics in medicine. 2007;26(1):53-77. [pmid: 16596572].
17 Rucker G, Schwarzer G, Carpenter J, et al. Why add anything to nothing? The arcsine difference as a measure of treatment effect in meta-analysis with zero cells. Statistics in medicine. 2009;28(5):721-738. [pmid: 19072749].
18 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Statistics in medicine. 2004;23(9):1351-1375. [pmid: 15116347].
19 Helfand M, Balshem H. AHRQ series paper 2: principles for developing guidance: AHRQ and the effective health-care program. Journal of clinical epidemiology. 2010;63(5):484-490. [pmid: 19716268].
20 Bevers TB, Anderson BO, Bonaccio E, et al. NCCN clinical practice guidelines in oncology: breast cancer screening and diagnosis. Journal of the National Comprehensive Cancer Network : JNCCN. 2009;7(10):1060-1096. [pmid: 19930975].
21 Kawachi MH, Bahnson RR, Barry M, et al. NCCN clinical practice guidelines in oncology: prostate cancer early detection. Journal of the National Comprehensive Cancer Network : JNCCN. 2010;8(2):240-262. [pmid: 20141680].
22 Mohler J, Bahnson RR, Boston B, et al. NCCN clinical practice guidelines in oncology: prostate cancer. Journal of the National Comprehensive Cancer Network : JNCCN. 2010;8(2):162-200. [pmid: 20141676].
23 Abulkhair O, Saghir N, Sedky L, et al. Modification and implementation of NCCN guidelines on breast cancer in the Middle East and North Africa region. Journal of the National Comprehensive Cancer Network : JNCCN. Suppl 3. 2010;8(S8-S15). [pmid: 20697133].
24 Hassen WA, Karsan FA, Abbas F, et al. Modification and implementation of NCCN guidelines on prostate cancer in the Middle East and North Africa region. Journal of the National Comprehensive Cancer Network : JNCCN. Suppl 3. 2010;8(S26-28). [pmid: 20697128].
25 Wallace BC, Small K, Brodley CE, et al. Toward modernizing the systematic review pipeline in genetics: efficient updating via data mining. Genetics in medicine : official journal of the American College of Medical Genetics. 2012. [pmid: 22481134].
26 Wallace BC, Trikalinos TA, Lau J, et al. Semi-automated screening of biomedical citations for systematic reviews. BMC bioinformatics. 2010;11(55). [pmid: 20102628].
27 Philips Z, Ginnelly L, Sculpher M, et al. Review of guidelines for good practice in decision-analytic modelling in health technology assessment. Health Technol Assess. 2004;8(36):iii-iv. ix. xi. 1. 158. [pmid: 15361314].
28 Ramsey SD, Sullivan SD. Weighing the economic evidence: guidelines for critical assessment of cost-effectiveness analyses. The Journal of the American Board of Family Practice / American Board of Family Practice. 1999;12(6):477-485. [pmid: 10612366].
29 Keeney RL, Raiffa H. Decisions with multiple objectives: preferences and value trade-offs. New York. Cambridge University Press. 1993.
30 Edwards P, Clarke M, DiGuiseppi C, et al. Identification of randomized controlled trials in systematic reviews: accuracy and reliability of screening records. Statistics in medicine. 2002;21(11):1635-1640. 12111924. [pmid: 12111924].
31 Robins JM, Scheines R, Spirtes P, et al. Uniform consistency in causal inference. Biometrica. 2003;90(3):491-515. PMID: N/A.
32 Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-634. [pmid: 9310563].
33 Sterne JA, Egger M. Funnel plots for detecting bias in meta-analysis: guidelines on choice of axis. Journal of clinical epidemiology. 2001;54(10):1046-1055. [pmid: 11576817].
34 Ioannidis JP, Trikalinos TA. The appropriateness of asymmetry tests for publication bias in meta-analyses: a large survey. CMAJ : Canadian Medical Association journal = journal de l'Association medicale canadienne. 2007;176(8):1091-1096. [pmid: 17420491].
35 Rucker G, Schwarzer G, Carpenter J. Arcsine test for publication bias in meta-analyses with binary outcomes. Statistics in medicine. 2008;27(5):746-763. [pmid: 17592831].
36 Harbord RM, Egger M, Sterne JA. A modified test for small-study effects in meta-analyses of controlled trials with binary endpoints. Statistics in medicine. 2006;25(20):3443-3457. [pmid: 16345038].
37 Moreno SG, Sutton AJ, Thompson JR, et al. A generalized weighting regression-derived meta-analysis estimator robust to small-study effects and heterogeneity. Statistics in medicine. 2012;31(14):1407-1417. [pmid: 22351645].
38 Peters JL, Sutton AJ, Jones DR, et al. Contour-enhanced meta-analysis funnel plots help distinguish publication bias from other causes of asymmetry. Journal of clinical epidemiology. 2008;61(10):991-996. [pmid: 18538991].
39 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343(d4002). [pmid: 21784880].
40 Hedges LV, Olkin I. Statistical methods for meta-analysis. San Diego, CA. Academic Press. 1985.
41 Burton A, Altman DG, Royston P, et al. The design of simulation studies in medical statistics. Statistics in medicine. 2006;25(24):4279-4292. [pmid: 16947139].
42 Hopewell S, Clarke M, Lefebvre C, et al. Handsearching versus electronic searching to identify reports of randomized trials. Cochrane Database Syst Rev. 2007;(2):MR000001. [pmid: 17443625].
43 Hopewell S, McDonald S, Clarke M, et al. Grey literature in meta-analyses of randomized trials of health care interventions. Cochrane Database Syst Rev. 2007;(2):MR000010. [pmid: 17443631].
44 Young T, Hopewell S. Methods for obtaining unpublished data. Cochrane Database Syst Rev. 2011;(11):MR000027. [pmid: 22071866].
45 Dwan K, Altman DG, Cresswell L, et al. Comparison of protocols and registry entries to published reports for randomised controlled trials. Cochrane Database Syst Rev. 2011;(1):MR000031. [pmid: 21249714].
46 Odgaard-Jensen J, Vist GE, Timmer A, et al. Randomisation to protect against selection bias in healthcare trials. Cochrane Database Syst Rev. 2011;(4):MR000012. [pmid: 21491415].
47 Welch V, Tugwell P, Petticrew M, et al. How effects on health equity are assessed in systematic reviews of interventions. Cochrane Database Syst Rev. 2010;(12):MR000028. [pmid: 21154402].
48 Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-186. [pmid: 9250191].
49 Godlee F, Gale CR, Martyn CN. Effect on the quality of peer review of blinding reviewers and asking them to sign their reports: a randomized controlled trial. JAMA : the journal of the American Medical Association. 1998;280(3):237-240. [pmid: 9676667].
50 McNutt RA, Evans AT, Fletcher RH, et al. The effects of blinding on the quality of peer review. A randomized trial. JAMA : the journal of the American Medical Association. 1990;263(10):1371-1376. [pmid: 2304216].
51 van Rooyen S, Godlee F, Evans S, et al. Effect of blinding and unmasking on the quality of peer review: a randomized trial. JAMA : the journal of the American Medical Association. 1998;280(3):234-237. [pmid: 9676666].
52 Shadish WR, Clark MH, Steiner PM. Can Nonrandomized Experiments Yield Accurate Answers? A Randomized Experiment Comparing Random and Nonrandom Assignments. J Am Stat Assoc. 2008;103(484):1334-1343. PMID: N/A.
53 Wood L, Egger M, Gluud LL, et al. Empirical evidence of bias in treatment effect estimates in controlled trials with different interventions and outcomes: meta-epidemiological study. BMJ. 2008;336(7644):601-605. [pmid: 18316340].
54 Willis BH, Quigley M. Uptake of newer methodological developments and the deployment of meta-analysis in diagnostic test research: a systematic review. BMC medical research methodology. 2011;11(27). [pmid: 21401947].
55 Austin PC. A critical appraisal of propensity-score matching in the medical literature between 1996 and 2003. Statistics in medicine. 2008;27(12):2037-2049. [pmid: 18038446].
56 Berkey CS, Hoaglin DC, Antczak-Bouckoms A, et al. Meta-analysis of multiple outcomes by regression with random effects. Statistics in medicine. 1998;17(22):2537-2550. [pmid: 9839346].
57 Turner EH, Knoepflmacher D, Shapley L. Publication bias in antipsychotic trials: an analysis of efficacy comparing the published literature to the US Food and Drug Administration database. PLoS medicine. 2012;9(3):e1001189. [pmid: 22448149].
58 Dahabreh IJ, Economopoulos K. Meta-analysis of rare events: an update and sensitivity analysis of cardiovascular events in randomized trials of rosiglitazone. Clin Trials. 2008;5(2):116-120. [pmid: 18375649].
59 Hernandez AV, Walker E, Ioannidis JP, et al. Challenges in meta-analysis of randomized clinical trials for rare harmful cardiovascular events: the case of rosiglitazone. American heart journal. 2008;156(1):23-30. [pmid: 18585493].
60 Friedrich JO, Adhikari NK, Beyene J. Inclusion of zero total event trials in meta-analyses maintains analytic consistency and incorporates all available data. BMC medical research methodology. 2007;7(5). [pmid: 17244367].
61 Wallace BC, Small K, Brodley CE, et al. Who should label what? Instance allocation in multipple expert active learning. Siam International Conference on Data Mining (SDM). 2011. 176-187. PMID.
62 Chu H, Cole SR. Bivariate meta-analysis of sensitivity and specificity with sparse data: a generalized linear mixed model approach. Journal of clinical epidemiology. 2006;59(12):1331-1332. author reply 1332-1333. [pmid: 17098577].
63 Macaskill P. Empirical Bayes estimates generated in a hierarchical summary ROC analysis agreed closely with those of a full Bayesian analysis. Journal of clinical epidemiology. 2004;57(9):925-932. [pmid: 15504635].
64 Rutter CM, Gatsonis CA. A hierarchical regression approach to meta-analysis of diagnostic test accuracy evaluations. Statistics in medicine. 2001;20(19):2865-2884. [pmid: 11568945].
65 Wallace BC, Dahabreh IJ, Trikalinos TA, et al. Closing the Gap between Methodologists and End-Users: R as a Computational Back-End. J Stat Softw. 2012;49(5):1-15. PMID: N/A.
66 Wallace BC, Small K, Brodley CE, et al. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the 2nd ACM SIGHIT International Health Informatics Symposium. 2012:819-824. PMID: N/A.
67 Wallace BC, Schmid CH, Lau J, et al. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC medical research methodology. 2009;9(80). [pmid: 19961608].
68 Diagnostic test accuracy working group: Handbook for diagnostic test accuracy reviews. 2011. http://srdta.cochrane.org/handbook-dta-reviews.
69 Harbord RM, Whiting P, Sterne JA, et al. An empirical comparison of methods for meta-analysis of diagnostic accuracy showed hierarchical models are necessary. Journal of clinical epidemiology. 2008;61(11):1095-1103. [pmid: 19208372].
70 Trikalinos TA, Olkin I. Meta-analysis of effect sizes reported at multiple time points: A multivariate approach. Clin Trials. Oct. 2012;9(5):610-20. [pmid: 22872546].
71 Trikalinos TA, Olkin I. A method for the meta-analysis of mutually exclusive binary outcomes. Statistics in medicine. 2008;27(21):4279-4300. [pmid: 18416445].
72 Petitti DB, Teutsch SM, Barton MB, et al. Update on the methods of the U.S. Preventive Services Task Force: insufficient evidence. Annals of internal medicine. 2009;150(3):199-205. [pmid: 19189910].
73 Methodological standards and patient-centeredness in comparative effectiveness research: the PCORI perspective. JAMA : the journal of the American Medical Association. 2012;307(15):1636-1640. [pmid: 22511692].
74 Djulbegovic B, Guyatt GH, Ashcroft RE. Epistemologic inquiries in evidence-based medicine. Cancer control : journal of the Moffitt Cancer Center. 2009;16(2):158-168. [pmid: 19337202].
75 Young JO. The Coherence Theory of Truth. Zalta EN, editor. The Stanford Encyclopedia of Philosophy. (Summer 2013) ed. Stanford, CA. The Metaphysics Research Lab, Stanford University. 2013. June 05, 2013.
76 David M. The Correspondence Theory of Truth. Zalta EN, editor. The Stanford Encyclopedia of Philosophy. (Summer 2013) ed. Stanford, CA. The Metaphysics Research Lab, Stanford University. 2013. June 05, 2013.