# Peer and Public Reviewers

- Benjamin Djulbegovic, M.D., Ph.D.
  Distinguished Professor of Medicine and Oncology at the University of South Florida & H. Lee Moffitt Cancer Center & Research Institute
  Tampa, FL
- Julian Higgins, Ph.D.
  Professor of Evidence Synthesis, University of York^*^
  * Affiliation during the peer review period
- Sally Morton, Ph.D.
  Professor of Biostatistics and Department Chair, University of Pittsburgh
  Pittsburgh, PA
- Members of the Institute for Quality and Efficiency in Healthcare (in German: Institut für Qualität und Wirtschaftlichkeit im Gesundheitswesenis)
- Members of the International Society for Clinical Biostatistics Subcommittee on Statistics in Regulatory Affairs