# Technical Expert Panel

- Benjamin Djulbegovic, M.D., Ph.D.
  Distinguished Professor of Medicine and Oncology at the University of South Florida & H. Lee Moffitt Cancer Center & Research Institute
  Tampa, FL
- David Moher, Ph.D.
  University Research Chair in Systematic Reviews, University of Ottawa
  Ottawa, Canada
- Sally Morton, Ph.D.
  Professor of Biostatistics and Department Chair, University of Pittsburgh
  Pittsburgh, PA
- Ingram Olkin, Ph.D.
  Professor Emeritus of Statistics and of Education, Stanford University
  Stanford, CA