# Acknowledgments

The authors gratefully acknowledge the Technical Expert Panel members, the peer and public reviewers for their constructive comments.