# Discussion

We have proposed a framework for evaluating methodological recommendations, and for organizing and describing the logic behind them. We started by defining the background context of the recommendations. We distinguish recommendations that are testable, in that their likelihood to hold can be informed by theory or data from nontestable ones, which represent beliefs or assumptions that are unknowable. Nontestable recommendations can be justified, but their validity cannot be demonstrated by means of a “test”. Testable recommendations can be assessed in terms of the adequacy of their evidentiary basis, the feasibility of following them, the expected impact of following them versus not, and their congruence with the requirements of the background context. Considering these four dimensions, one might opine if a recommendation is a minimum standard or a mandatory item, a desirable (but not mandatory) item, or something in between.

We believe that a recommendation should be made only for problems that are well understood, and when the recommended choice is on average and under usual conditions a clearly “beneficial” one. This is somewhat unfulfilling, in that recommendations will be sparse for problems for which guidance is most necessary. Conversely, recommendations would be more specific for problems where the optimal solutions are known. However, our position is that recommendations should generally be followed, and therefore a stringent approach is reasonable. We believe such stringency is observed in the IOM and MECIR recommendations: they are more numerous and more specific on processes (e.g., forming the review team, refining the topic, managing conflict of interest), but provide only generic guidance on exactly how to synthesize evidence. Guidance can (and arguably should) be provided when dealing with difficult problems, with the understanding that the suggested approaches may not be optimal.

We are ambivalent about the need for explicit scoring of testable statements on their four dimensions. Explicit scoring of individual dimensions is as subjective as rating the overall strength of the recommendation. It is conceivable that the same recommendation could receive different descriptions in some dimensions (e.g., feasibility of implementation, congruence with context-specific requirements), given different background contexts. On the other hand, explicit scoring could be used to abstract the logic for deducing whether the recommendation is a mandatory item or a desirable but not mandatory practice. We lean in favor of avoiding explicit scoring of the individual dimensions.

The proposed framework calls for a structured set of subjective judgments. Extensive as they may be, the subjectivity in rating the dimensions of testable statements, and the fuzziness of the dimensions themselves are probably much less extensive than the subjectivity and fuzziness of recommendations that do not have a defined background context, are composites of testable and nontestable statements, are in want of an organized categorization of their supporting information, or fail to distinguish considerations on feasibility from the expected impact of following the recommendation. We therefore maintain that more structured approaches such as the one proposed here will serve the methodological community better than less structured ones.

We believe that our framework represents a more general and more structured alternative to the approaches used to date by those who make methodological recommendations (for example the IOM panel, the MECIR authors, or the PCORI methodology committee), but it does not represent a dissent. Using the framework can help communicate subtle but important aspects of the recommendation at hand. For example, we selected element 3.3.3 in the IOM report (example R1,^k^ which is similar to standard #C39 in MECIR) to illustrate our framework. We would probably agree with IOM and MECIR that this recommendation should be followed if the only alternative is single screening, but point out that as more options become available (e.g., computer-aided screening by humans), this recommendation might change.

k “Use two or more members of the review team, working independently, to screen and select studies”

In practice, an additional complication arises: When many methodological recommendations are made that tax resources and demand expertise, adhering to all of them can be a rather expensive proposition, even within well-funded programs. Deciding which recommendations are most important to adhere to and which are not is very difficult. In theory, those making the recommendations might try to rank them by relative merit, given the expected resource constraints, by following the same process as we discussed here for single recommendations. In reality this is impractical. For example, the feasibility of implementation is consumer-dependent, e.g., some systematic review teams have extensive expertise, others less so. It is also domain- and topic-dependent, in that adhering to all recommendations is feasible for reviews of small enough scope. Analogous considerations apply to the impact of the implementation. Fine tuning the relative merit of a large number of recommendations is thus too much to ask of those providing general methodological guidance, e.g., the IOM or Cochrane's MECIR. By contrast, very explicit prioritizations can be meaningful in narrow contexts, e.g., when developing internal guidance for a specific program or team. In the end, systematic reviewers will prioritize the methodological recommendations they can adhere to when they do a systematic review, given their operational abilities and budget.

Deeper epistemological and philosophical discussions can be had with respect to the validity or “truth” of methodological recommendation statements. The device employed in this work, namely distinguishing testable from nontestable statements, is utilized without explicit (at least without conscious or intended) reference to philosophical theories of truth. Djulbegovic et al. posit that Evidence-based Medicine as a (still evolving) structure for optimizing clinical practice that draws on several major philosophical theories of scientific evidence, but is in want of a rigorous epistemological stance. The proposed framework for communicating the strength of methodological recommendations is analogously (non)nuanced epistemologically: our designation of (empirically) nontestable statements draws from the coherence theory of truth, according to which a statement is considered true if it squares with other statements. The origins of nontestable statements can be traced, because they are developed within a historical body of knowledge in which the arguments strive to be internally consistent. So, ideally each (empirically) nontestable statement should be referred to the body of knowledge that led to its inclusion in the recommendations—a daunting but not impossible task. By contrast, our (empirically) testable statements reflect the correspondence theory of truth, in which arguments correspond with reality, and “truth” is based on the correspondence of ideas with facts.

The feasibility and ease of applying the proposed framework itself is not clear. Further, the framework is quite general, in that it could be applied to methodological recommendations in other domains, beyond systematic review and meta-analysis. Broader application may provide insights or make obvious the need for modifications or larger changes. It is the nature of methods to change, to evolve, and so will this proposal.