# Developing the Framework

We started by generating several dozens of hypothetical recommendation statements on methodological decisions often encountered when performing systematic reviews and meta-analyses. The methodological decisions spanned the entire systematic review process, including: developing and refining Key Questions; identifying and appraising relevant evidence; extracting data; conducting meta-analyses or qualitative syntheses and presenting findings. The recommendation statements we considered varied in the degree of specificity and technical sophistication. We went through an iterative process of analyzing and discussing these candidate recommendation statements to identify an initial set of potential components for an evaluative framework.

Early versions of the framework were modified based on feedback from (1) two discussion sessions with researchers and faculty at the Center for Clinical Evidence Synthesis, Tufts Medical Center and Tufts University; (2) individual teleconference or in-person sessions with a Technical Expert Panel comprising of five internationally recognized experts in systematic review and meta-analysis; (3) a 40 minute discussion at the 2011 Society for Research Synthesis Methodology^a^ meeting; and (4) an external peer and public review process. While the version of the framework presented here incorporates feedback obtained from these sessions, it is the opinion and construct of the authors, and does not necessarily reflect the opinions of the TEP or other experts who were engaged during its development.

a The authors of the report are members of said society.