# Description, Explanation, and Elaboration

Methodological recommendations provide guidance for action when facing a choice between alternative methods. Table 1 shows three example recommendations for systematic review and meta-analysis obtained from IOM, MECIR or Agency for Healthcare Research and Quality (AHRQ) guidance. The first (R1) prescribes an optimal approach (optimal in some yet unstated sense) to identify eligible studies for a systematic review among the citations returned by the searches, as compared with other (yet unstated) approaches. The other two recommendations (R2 and R3) pertain to questions of a statistical nature. R2 provides guidance for choosing a meta-analytic method for studies with rare events. R3 advises on the choice between random effects and equal (“fixed”) effects modeling for studies of diagnostic test accuracy. Throughout this work we use example recommendation statements for exposition, such as the ones in Table 1. We describe them from the perspective of someone who would make such a recommendation, even in cases where we are not in complete agreement with the contents of the recommendation being discussed.

Table 1 Example methodological recommendation statements

# | Recommendation | Source^*^
R1 | Use two or more members of the review team, working independently, to screen and select studies | IOM, element 3.3.3.^†^ and MECIR, #39^‡^
R2 | Use the Peto or the Mantel-Haenszel method for meta-analysis of rare events | AHRQ guide (reworded)^§^
R3 | Use a random effects model for diagnostic test meta-analysis | AHRQ guide (reworded)^‖^

AHRQ = Agency for Healthcare Research and Quality; IOM = Institute of Medicine; MECIR = Methodological Expectations of Cochrane Intervention Reviews

* Similar recommendations have been made by other entities (not cited).

† Finding what works in healthcare. Standards for systematic reviews.1

‡ Methodological standards for the conduct of new Cochrane intervention reviews.2

§ Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program.3

‖ Meta-analysis of test performance when there is a “gold standard.”4

The framework outlined in Figure 1 is intended to help those developing methodological guidance to explain the rationale behind their choices. It comprises a series of four steps described in the following sections. Specifically, Define the Background Context (Step 1) explains what is needed to define the methodological challenge addressed by the recommendation. Decompose the Recommendation into Testable and Nontestable Parts (Step 2) explains how to break down (decompose) complex recommendations into more manageable parts. Describe Statements in Four Dimensions (Step 3) deals with assessing the logic behind the recommendation statement, its support, applicability, and anticipated impact; and Opine on Whether a Recommendation Constitutes a Mandatory Item or a Desirable (but not Mandatory) Item (Step 4) describes how to communicate one's confidence that the recommendation should be followed.

Figure 1 Overview of the proposed framework for rating the strength of methodological recommendations

SR = systematic review

Note: Bold horizontal lines define sequential steps. See text for explanation and elaboration.

Figure 1 shows an outline of the proposed framework. It includes 4 steps. The first is to define the background context (including the setting, the problem, the choices, the perspective and the measures to optimize). The second step is to decompose the recommendation into testable and nontestable statements. The third step is to describe each statement in four dimensions: All statements can be described in terms of feasibility of implementation, expected practical impact of implementation and congruence with context specific requirements. Testable statements can be described in terms of their evidentiary basis (including mathematical and technical arguments, empirical evidence of large scale, case studies, or expert opinion), and nontestable statements can be describd in terms of face-validity. The fourth step is to opine on whether the recommendation constitutes a mandatory item, a desirable but not mandatory item, or something in between, on the basis of the descriptions in the third step. Mandatory items are those for whih most peers agree that systematic reviews not following the recommendation are likely to be misleading. Desired but not mandatory are items for which most peers agree that it is desirable to follow them, but failure to do so does not render the systematic review misleading.

## Define the Background Context (Step 1)

All recommendations require a background context that specifies the problem being addressed and prescribes the desired characteristics of an optimal solution to the problem. The background context describes: (1) the setting; (2) the problem at hand; (3) a finite set of alternative choices for addressing the problem; (4) the perspective of the recommendation; (5) and, a set of measures with respect to which one can rank alternative choices. As an example, Table 2 reconstructs the presumed background context of R1 using information from the IOM report and from other sources. Table 3 and Table 4 provide background contexts for R2 and R3, respectively.

Table 2 Background context for recommendation R1 (“Use two or more members of the review team, working independently, to screen and select studies”)

# | Element of the Background Context | Description
1 | Setting | Publicly funded SRs in health care
2 | Problem | Identify all eligible studies for a SR among citations returned by searches
3 | Alternative choices | a. Single human reviewer; b. Computer-assisted screening; c. At least two human reviewers (independently); d. At least two nonindependent human reviewers (nonindependently); e. Human plus computer-assisted screening (independently); f. Human plus computer-assisted screening (not independently)
4 | Perspective | That of the funder of the SR (public agency such as AHRQ) or of the user of the SR (including decision makers and other consumers). Desired attributes of SRs:^*^ Credibility Generalizability Efficiency Patient centeredness Scientific rigor Timeliness Transparency
5 | Measures to optimize | Minimize the likelihood of missing eligible research; maximize the efficiency and timeliness of SR; maximize SR credibility.

AHRQ = Agency for Healthcare Research and Practice; SR = systematic review

Note: This background context was constructed using information from the IOM report “Finding What Works in Healthcare.”

* Finding What Works in Healthcare. Standards for Systematic Reviews. Washington, DC: Institute of Medicine of the National Academies; 2011.

Table 3 Background context for recommendation R2 (“Use the Peto or the Mantel-Haenszel method for meta-analysis of rare events”)

# | Element of the Background Context | Description
1 | Setting | [Same as R1]
2 | Problem | Combining odds ratios in meta-analyses of at least 5 studies, most of which have rare events (<5% event rate per arm).
3 | Alternative choices | Equal effect (“fixed effects”) model Peto method Mantel-Haenszel method Inverse-variance method (fixed effect) Logistic regression (fixed effect) Exact logistic regression Random effects model Normal within-/normal between-study variance, noniterative estimation (e.g., DerSimonian-Laird) Normal within-/normal between-study variance, iterative estimation (e.g., REML) Binomial within-/normal between-study variance, iterative estimation (e.g., ML)
4 | Perspective | [Same as R1]
5 | Measures to optimize | Statistical bias; coverage probability; mean squared error; feasibility of implementation; SR/meta-analysis credibility.

ML = maximum likelihood; REML = restricted maximum likelihood; SR = systematic review

Note: The Table is for exposition, and was constructed using information from EPC Methods guidance documents and from our own experience as authors of EPC Methods guidance (see reference: Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011 Nov;64(11):1187-97.) A preference for using the odds ratio as the metric of interest is implicit here.

Table 4 Background context for recommendation R3 (“Use a random effects model for diagnostic test meta-analysis”)

# | Element of the Background Context | Description
1 | Setting | [Same as R1]
2 | Problem | Estimating average sensitivity and specificity in a meta-analysis of at least 10 studies
3 | Alternative choices | Always use random effects modeling Always use equal effect modeling Choose between random and equal effect modeling on the basis of model best fit to the data at hand
4 | Perspective | [Same as R1]
5 | Measures to optimize | Maximize the generalizability of SR/meta-analysis findings.

SR = systematic review

Note: The table is for exposition, and was constructed using information from EPC methods guidance documents (see reference 4: Trikalinos TA, Balion CM, Coleman CI, et al. Chapter 8: meta-analysis of test performance when there is a “gold standard”. J Gen Intern Med. Jun 2012;27 Suppl 1:S56-66.)

### Setting

Recommendation R1 refers to publicly funded systematic reviews in health care. It is not necessary that R1, or any recommendation for that part, be transferable to settings other than the intended one. Minimum standards in the setting of publicly funded systematic reviews may be held to be desirable but not necessary in settings of very limited resources. For example, researchers in fields such as evolutionary biology and ecology (in which funding for systematic reviews from any source is scarce compared with health care) might find this recommendation exceedingly challenging to follow [personal communication, Prof. Jessica Gurevitch, State University of NY]. The observation that methodological recommendations are embedded in specific settings is directly analogous to clinical practice guidelines that are also setting-specific. For example, the National Comprehensive Cancer Network guidelines for breast cancer screening, or prostate cancer screening and management referred primarily to health care systems in developed economies and had to be modified for use in developing countries.

### Problem

A concise and unambiguous description of the challenge addressed by the recommendation.

### Alternative Choices

For R1, we have at least six reasonable options, which are combinations of (1) whether the screening is done in a single pass or with redundant^b^ efforts (e.g., in duplicate); (2) whether the redundant screening efforts are independent or not; (3) and whether screening is conducted by unaided humans, or by humans using computer-assisted processes. Currently, all six options have been implemented in applied and methodological research projects. The advantages and disadvantages of the six options can to some extent be captured by specific measures (see below). Considering all realistic alternatives is important for an analysis of any decisional problem, and this includes making methodological recommendations. Only choices included in the list of alternatives will be considered. Consequently, if the optimal choice is not among them, it will not be selected. In this example, the IOM report alluded to only two of the six choices, namely, independent redundant screening versus single screening by unaided humans (choices c versus a in Table 2; we will return to this in the section on step 4).

b We use “redundant efforts” in the Quality Control sense, i.e., processes that occur in parallel to increase the reliability of a system; we do not use the colloquial meaning of redundancy as a synonym of inefficiency.

Table 3 and Table 4 list alternative choices for R2 (methods for meta-analyzing odds ratios when events are rare) and R3 (choosing between random and equal [“fixed”] effects models for diagnostic test meta-analysis), respectively. These two examples provide the full choice sets considered by those making the recommendations.

### Perspective

Funders of systematic reviews and meta-analyses, those who conduct them, and their consumers have different perspectives on which attributes of a systematic review or a meta-analysis are most important. Presumably all would agree that systematic reviews should be credible, scientifically rigorous, transparent, timely and generalizable. However, the cost associated with the production of systematic reviews is probably more important to funders and those who conduct the research than to consumers. On the other hand, consumers have a key interest in patient-centered conclusions.

Many methodological recommendations are developed from the perspective of the entity that oversees the production of the systematic reviews. This can be a funding agency such as AHRQ, a nonprofit entity such as the Cochrane Collaboration, a professional society, a for-profit contract research organization, or an industrial firm performing an in-house assessment of one of their products. The perspective prescribes the desired attributes of systematic reviews that will be produced using the methodological guidance. In turn, the desired attributes of the systematic reviews prescribe which measures are deemed important for choosing among the alternative choices. Helfand and Balshem state that systematic reviews produced by AHRQ should fully explore the clinical logic behind the reviewed questions, make use of best evidence for each type of question, provide a balanced assessment of benefits and harms, and manage conflict of interest responsibly. For our examples, we specify seven desired attributes of systematic reviews (Table 2, row 4) based on the rationale articulated in the introduction of the IOM report.^c^

c A subtle difference: the IOM panel describes these seven attributes as “criteria” for developing their methodology standards, in the sense that the panel selected standards that promote reviews with these attributes.

### Measures To Optimize

The background context should specify one or more measures with respect to which the alternative choices may be compared. A plausible interpretation of the background context for R1 is that the goal is to minimize the likelihood of missing research that would change the decisions informed by the systematic review. Plausible measures that can be used to operationalize whether these goals are achieved thus can include the number of eligible studies that are missed (which should be minimized); the efficiency of the process, and the timeliness and credibility of the systematic reviews that will be generated (which should be maximized) (Table 2). It is reasonable to choose other measures in place of those proposed here. It is also reasonable to assign different importance or weight to each measure. The four measures proposed for R1 (row 5 in Table 2) are not readily quantifiable in a practical manner (though other, readily quantifiable measures can be used instead). However stating them promotes transparency, and using them in a qualitative fashion helps communicate the rationale for the final recommendation.

By contrast, for technical (e.g., statistical) problems it may be feasible to define quantitative measures. For example, for R2 it is reasonable to choose measures that quantify the statistical performance of alternative meta-analysis methodologies, including the method's statistical bias (desired to be zero), actual coverage probability of 95% confidence intervals (desired to be nominally 0.95), and mean square error (desired to be as small as possible).

Finally, the background context for R3 specified a single measure to optimize, i.e., that the findings of the synthesis should be generalizable to all studies that are similar to those included in the meta-analysis. When there is only one measure to optimize the alternative choices can be ranked readily. R1 and R2 specified more than one measure to optimize, and it is possible that no single choice is optimal on all measures. Those making recommendations R1 and R2 (or any other recommendations with multiple measures to optimize) have to specify how much they care for each measure, explicitly or implicitly. Specifically, for R2, bias and mean square error can operate in opposite directions, because mean squared error incorporates both bias and variance. Thus, those making the recommendation must decide which measure they care most about, or more generally, how to incorporate the multiple measures in their decisionmaking. This challenge is more formally studied in the context of decision making with multiple objectives, or multi-attribute or multi-criteria decision analysis.

## Decompose the Recommendation Into Testable and Nontestable Parts (Step 2)

It is important to distinguish between two types of statements found in methodological recommendations: those that can be tested in a practical manner, and those that cannot.

### Testable Statements

Statements are testable when a procedure (“test”) exists that can inform on the likelihood that the statement holds. R1 and R2 contain such testable statements. For R1, it is practical to compare empirically the six alternative choices listed in Table 2 in a sizable number of systematic reviews. In fact, human screening in one pass has been compared with double independent screening, and computer-assisted screening has been compared with human-only screening in limited settings. Similarly, for R2 it is practical to compare the alternative choices in Table 3 according to their statistical performance in simulation studies.

In addition, it is expected that most peers will agree that properly selected procedures or tests can inform choices between the alternatives in each background context, although they may still disagree on exactly how to interpret the information.

### Nontestable Statements

By contrast, R3 is different in a subtle but important way. R3 describes an attribute of the generative model (the model that describes the data generation process) in a meta-analysis. Thus, R3 describes a belief about the (unobserved and unknowable) process by which diagnostic accuracy studies are generated. The alternatives considered in Table 4 include random effects modeling, equal (“fixed”) effect modeling, and choosing between the random and equal effects on the basis of model fit to data, i.e., on the basis of a heterogeneity test. R3 favors random effects modeling; while R3 can be motivated, it is not empirically testable. This is because, in general, data do not suffice to determine the underlying statistical model.^d^ In particular, model fit cannot be used to infer the correct model, an intuition that has been conveyed in standard meta-analysis texts by advising to choose between equal (“fixed”) and random effects a priori, and not on the basis of heterogeneity testing (Cochran's Q can be considered a measure of model fit).

d The exception is when one is aware of, and can measure and control for all existing confounders, and knows the time order of events: this is by design possible in a single randomized trial, but not in general –see reference 31, Robins JM, Scheines R, Spirtes P, et al. Uniform consistency in causal inference. Biometrica. 2003;90(3):491-515. , on the nonexistence of uniform consistency in causal inference.

So how does one choose the underlying true model in a meta-analysis? In the meta-analysis case, and for the alternatives in Table 4, we have some intuition about the attributes of study generating processes. With trivial (and exceedingly uncommon) exceptions, the equal (“fixed”) effect scenario, which postulates that all studies have the same true effect and differ only because of sampling error, is implausible: studies in a meta-analysis are unlikely to estimate a single true effect because they differ in terms of populations, interventions, comparators and outcomes, and in the details of their design and execution. It is therefore reasonable to choose random effects modeling over equal (“fixed”) effect modeling.

Those making recommendation R3 apparently forgo the choice of data-driven model selection, presumably because they are comfortable in specifying the plausible model a priori. This is relatively straightforward for the background context in Table 4. In some sense, choosing between only two simple models is a “luxury” one has in the simple meta-analysis case. In other statistical problems (perhaps problems posed in a more nuanced way than R3 and), an a priori choice may be less straightforward, and many may reasonably choose the pragmatic approach of guiding model choice on the basis of model fit.^e^

e Relying on model fit has implications on the interpretation and contextualization of findings.

Others^f^ may add more alternative choices in Table 4, reflecting different understandings of the plausible data generation process, or a different stances to model selection altogether. In the judgment of those making the recommendation, R3 is acceptable in the given background context: peers can legitimately disagree about the acceptability of nontestable statements.

f A recommendation-making body other than the “hypothetical” one that made R3.

Preferably, methodological recommendations should contain testable statements, and, as feasible, keep nontestable statements to the necessary minimum. Further, as described next, it is preferable to avoid recommendations that mix together testable and nontestable statements.

### Decomposition of Recommendations That Include Testable and Nontestable Statements

#### A Simple Example

Recommendations R1, R2 and R3 are simple, in that they contain only testable or only nontestable statements. Composite recommendations include both testable and nontestable statements. For exposition, consider a composite hypothetical recommendation, within the background context in Table 5:

R4 Use a generalized random effects linear model (random effects logistic regression fit by maximum likelihood) to obtain summary odds ratios in a meta-analysis of binary data.
  R4 can be decomposed into a nontestable statement:
  R4.1 Use (i) a random effects model for the meta-analysis, and (ii) the odds ratio as the analysis metric, and a testable statement:
  R4.2 Given R4.1, use a generalized random effects linear model (random effects logistic regression fit by maximum likelihood) to obtain the summary odds ratio.

Table 5 Background context for a composite recommendation statement constructed for exposition

R4 “Use a generalized mixed effects linear model (random effects logistic regression fit by maximum likelihood) to obtain summary odds ratios in a meta-analysis of binary data”

# | Element of the Background Context | Description
1 | Setting | [Same as R1]
2 | Problem | Combining odds ratios in meta-analyses of at least 10 studies with dichotomous outcomes (>5% event rate per arm)
3 | Alternative choices | Homogeneous effect Peto method (odds ratio metric) Mantel-Haenszel method (various metrics) Inverse-variance method (normal within study variance; various metrics) Logistic regression (binomial within study variance; odds ratio metric) Random effects Noniterative estimation of heterogeneity (inverse-variance, DerSimonian Laird; various metrics) Iterative estimation of heterogeneity (REML, normal-normal model; various metrics) Random effect logistic regression (ML, binomial-normal model; odds ratio metric)
4 | Perspective | [Same as R1]
5 | Measures to optimize | Maximize the generalizability of SR findings Statistical bias; coverage probability; mean squared error; maximize feasibility of implementation; maximize SR/meta-analysis credibility.

ML = maximum likelihood; REML = restricted maximum likelihood; SR = systematic review

Note: This recommendation is a composite recommendation (see text).

The first part (i) of R4.1 is similar to R3, and has been discussed already. Part (ii) specifies using the odds ratio instead of the risk ratio, the risk difference, or other, less commonly considered metrics such as the difference in entropy or the Kullback-Leibler divergence. The choice of the metric is arbitrary but motivated. It is arbitrary, because the alternative options included only the small set of metrics traditionally used in clinical research. It is motivated, because it coheres with other methods choices that are common in clinical research, with statistical and epidemiological theory, and with common practices. Further—and this may be important to those making the recommendation—the log odds ratio is symmetric whereas the log risk ratio is not; and its range is the whole real axis, whereas the range of the risk difference is from -1 to +1. In all, R4.1 is not testable in a practical manner. Like R3, from the perspective of those making the recommendation, R4.1 is either acceptable or not—one can motivate its selection to communicate why it is deemed reasonable, but cannot prove its validity.

By contrast R4.2 pertains to a statistical methodology, and its likelihood to hold (for example, in terms of statistical performance) can be evaluated with well-established methods. It is easier to think about the decompositions R4.1 and R4.2, rather than the composite statement R4 on its own. The following sections pertain to a real recommendation statement that is probably better handled after it has been decomposed into testable and nontestable parts.

#### Asymmetry in Funnel Plots

Composite recommendations can be difficult to appreciate, and can lead to protracted and nonproductive discourse. The case of the funnel plot as an aid to detect publication bias is such an example. Funnel plots were introduced in the mid-1980s as a means to assess the likelihood of publication bias. In brief, publication bias is present when studies with statistically significant results are more likely to be published than those with statistically nonsignificant results. This phenomenon biases summaries of published data. The motivation for funnel plots is simple. If all studies are generated from a single underlying unimodal distribution,^g^ a scatterplot of observed study effects on the horizontal axis and their precision on the vertical axis would resemble a symmetric inverted funnel in the absence of publication bias or an asymmetric inverted funnel in the presence of publication bias (and assuming the generative story described below). The original paper emphasized that this test was valid in the equal effect setting. A seminal paper in the British Medical Journal popularized a method for testing for funnel plot asymmetry. Its authors were very careful to explain that publication bias is only one of many explanations of funnel plot asymmetry, but many others have chosen to ignore this advice. It is now common in the medical literature that authors use funnel plot asymmetry as a test for publication bias under either equal or random effect models.

g See later in this section for a more explicit description.

The misuse of funnel plots in the literature has spurred an academic exchange with very little cross-talk between those who do not accept that funnel plot asymmetry is particularly informative on the likelihood of publication bias, and others who opted to focus on developing improved statistical tests and other methods for assessing funnel plot asymmetry. The parallel monologues continued in a methodological discussion in the Cochrane Collaboration, where the discussants agreed on technical aspects of testing for asymmetry, but disagreed about their informativeness. Academics from both sides of the discussion published consensus guidance on the interpretation of funnel plot asymmetry and the use of pertinent tests.

Nevertheless, to demonstrate how one might put these considerations into the proposed framework, we paraphrase the MOOSE group's advice that “methods should be used to aid in the detection of publication bias, e.g., fail-safe methods or funnel plots”, and construct a hypothetical recommendation within the background context in Table 6:

R5 Use a regression of effect size versus its precision to test for publication bias in a meta-analysis.
  R5 is vague, in that Table 6 does not state a generative model that includes publication bias. To identify the publication bias from the pattern of published studies, one has to state assumptions about (the details of) the process that generates studies and the process that censors study publication (or their complete reporting). With that in mind, R5 can be decomposed into a nontestable statement (embellished using rather typical assumptions):
  R5.1 The generative model for publication bias comprises (i) study effects generated according to an equal effects model (i.e., the between study variance is 0), and (ii) a selection process, where the probability that study i is published is a function of z_i_ = d_i_/s_i_, with d_i_ the observed effect (log odds ratio) and s_i_^2^ its sampling variance;
    and a testable statement:
  R5.2 Given R5.1, regress the effect size d_i_ versus its precision1/s_i_ and deduce that the funnel plot is asymmetric if the regression slope is different than 0.

Table 6 Background context for recommendation R5.1 (describing a generative model for publication bias—see text)

# | Element of the Background Context | Description
1 | Setting | [Same as R1]
2 | Problem | Assessing the likelihood of publication bias in a meta-analysis of at least 10 studies.
3 | Alternative choices | Study effects are generated under an equal effects model. It is also assumed that the probability that studies are selected for publication as a function on the ratio z_i_ = d_i_/s_i_, where d_i_ is the treatment effect and s_i_ the sampling variance of study i. [Other generative models, e.g. models where the data generation process follows a random effect model, or where the probability that a study is selected for publication can be a function of d_i_ and s_i_ separately, rather than their ratio z_i_.]
4 | Perspective | [Same as R1]
5 | Measures to optimize | Minimize the likelihood of missing eligible research; maximize the efficiency and timeliness of SR; maximize SR credibility.

SR = systematic review

Note: This is the first part of the decomposition of a recommendation made by the MOOSE group on using funnel plots for assessing the presence of publication bias (see text). We (the authors) have little insight into the deliberations of MOOSE and thus make a good faith effort to reconstruct a plausible context. Other contexts can be constructed – but the current should suffice for exposition.

The first statement (R5.1) is nontestable in that it describes an explicit model for processes that are complex and unobservable. (Other explicit versions of R5.1 are possible, and any of them, including this one, would suffice for the sake of exposition.) R5.1 implies that funnel plot asymmetry is the manifestation of publication bias. Given R5.1, funnel plot asymmetry detected by following R5.2 should be interpreted as (i) publication bias, (ii) a statistical artifact (e.g., asymmetry induced by the correlation between the log-odds ratio and its precision), or (iii) as a chance finding (type I error). Only symmetric funnel plots are generated in the universe of R5.1, to be rendered asymmetric through the censoring/selection process of publication bias. For example, R5.1 does not provide for a bimodal study generating distribution, i.e., for an intervention with different effects across two population strata. In such a case funnel plot asymmetry might arise without publication bias, if studies were designed efficiently: smaller (less precise) studies might be designed in the larger effect stratum, and larger (more precise) studies in the smaller effect stratum (example drawn from reference). In all, however, R5.1 is not empirically testable in a practical manner.

By contrast, R5.2 is testable in a practical manner, e.g., through simulation studies comparing alternative statistical tests (Table 7). The aforementioned consensus publication succeeds in focusing on testable statements, and avoids specifics on nontestable ones (said publication does not make explicit distinctions between testable and nontestable statements).

Table 7 Background context for recommendation R5.2 (“Given R5.1, regress the effect size d_i_ versus its precision 1/s_i_ and deduce that the funnel plot is asymmetric if the regression slope is different than 0”)

# | Element of the Background Context | Description
1 | Setting | [Same as R5.1 – see Table 6]
2 | Problem | Assessing the likelihood of publication bias in a meta-analysis of at least 10 studies.
3 | Alternative choices | Infer about the likelihood of publication bias based on funnel plot asymmetry Use a regression test of effect size versus its precision Use the trim-and-fill method Use visual inspection of contour enhanced funnel plots Infer on the likelihood of publication bias using selection models Search clinical trial registries and other sources and contact manufacturers to identify unpublished data [… another 4 options, combination of (c) with each of (a.i), (a.ii), (a.iii) or (b)]
4 | Perspective | [Same as R5.1]
5 | Measures to optimize | Minimize the likelihood of excluding the presence of publication bias

Note: This is the second part of the decomposition of a recommendation made by the MOOSE group on using funnel plots for assessing the presence of publication bias (see text). We (the authors) have little insight in to the deliberations of MOOSE and thus make a good-faith effort to reconstruct a plausible context. Other contexts can be constructed, but the current should suffice for exposition.

## Describe Statements in Four Dimensions (Step 3)

The next step is to evaluate recommendations with respect to four dimensions: (1) face-validity (for nontestable statements only) or scientific rigor and (adequacy of) evidentiary basis (for testable statements only), (2) feasibility of implementing the recommendation (for all statements), (3) expected practical impact of implementing the recommendation (for all statement), and (4) congruence with context-specific requirements (for all statements). It is unclear whether qualitative descriptions are sufficient, or whether they should be further summarized by an explicit score for each dimension. To avoid encouraging an algorithmic and uncritical application of this framework we favor qualitative descriptions.

### Face-Validity (for Nontestable Statements Only); and Scientific Rigor or Adequacy of Evidentiary Basis (for Testable Statements Only)

For nontestable statements, or nontestable parts of composite recommendations, those making the methodological recommendation should provide a justification. The justification should help readers understand the viewpoint of the nontestable recommendation, and explain why it has face validity. For example, those making the recommendation R3 (using random effects models for diagnostic test meta-analysis) may motivate their choice based on their assessment that a random effect model is a more plausible data generation model than an equal (“fixed”) effect one. R4.1 (the nontestable part of R4) is similar to R3, and may be motivated using an analogous justification. R5 (and its decomposition into R5.1 and R5.2) was constructed for exposition, based on the MOOSE group statement. We (the authors) have little insight into the deliberations of MOOSE and thus make a good faith effort to reconstruct a plausible context and justification for it. For the record, we (the authors) do not agree with R5.1 (and thus with R5): We believe that R5.1 is probably too simplistic to be useful for identifying publication bias. Others can disagree. Being explicit can help identify the points of disagreement.

For testable statements, this dimension informs the likelihood that the statement holds, by evaluating the arguments or data that support it. As is the case for clinical practice guidance where current thinking favors different study designs for different tasks such as measuring the effectiveness of interventions, the safety of interventions, or the accuracy of medical testing, no single hierarchy of arguments or data applies to all testable methodological recommendations. We first describe broad categories of supporting information, and then suggest which to prefer for commonly encountered types of testable recommendations.

#### Categories of Supporting Information for Testable Statements

For description, we distinguish four categories of supporting information: (1) mathematical and technical arguments including statistical simulations; (2) empirical data of large scale; (3) case studies; and (4) expert opinion.

The first category of mathematical and technical arguments includes knowledge and information that can be generated largely without collecting empirical data. This includes mathematical derivations and proofs, and theoretical explorations in the form of simulation analyses. Mathematical and technical arguments are most pertinent to recommendations of a technical nature. For example, it is easy to show that in a pairwise meta-analysis of intervention studies, naïve pooling (where one first combines proportions of events within treatments, and then calculates differences between treatments) yields a summary treatment effect estimate that is confounded by study. In another example, a theorem proves that normalized weights that are inversely proportional to the sampling variance in each study yield the most efficient estimator of the summary effect in a meta-analysis of normally distributed data compared with other linear weighting schemes (e.g., by sample size, or by inverse-standard error).

Statistical simulation studies can be very informative, especially when mathematical proofs are too difficult or impossible to derive. Simulations are very useful for comparing the statistical performance of methods, but they can only examine a relatively small number of scenarios. To derive more general conclusions, one must interpolate or extrapolate the simulation findings to address scenarios that have not been examined. Simulation studies have to follow good design practices to be robust and applicable to real-life situations. Judging whether a simulation study is comprehensive or convincing requires content expertise and solid understanding of the methods being examined and of the background context of the methodological recommendation made. Almost invariably, this requires statistical expertise.

Empirical data of large scale^h^ should be identified by means of methodology systematic reviews, such as the ones conducted by the Cochrane Methodology Review Group to inform the methods guidance provided by the Cochrane collaboration. Empirical data are obtained by means of randomized, case-control, cohort, survey or other designs. Thus, there is substantial variation in terms of evidentiary strength. Randomized trials comparing research methodologies are relatively uncommon. Examples include a randomized comparison of blinding versus not blinding of data extractors to the names and affiliations of primary study authors, which showed no difference in the accuracy of data extraction, but a substantial difference in the overhead and cost of performing a meta-analysis (higher in the blinding arm). Not directly relevant to meta-analysis, randomized trials have been used to examine the effects of blinding vs. not blinding reviewers to author identities in journal peer-review, and having eponymous versus anonymous peer-reviewers. An ingenious study attempted to compare alternative study designs by randomizing participants to receive random versus nonrandom assignments, to empirically assess whether analysis of observational data can yield accurate answers.

h “Large scale” means empirical data that include more than a couple of anecdotal examples. Of course, the exact number of examples included in these data will differ.

Much more common are observational studies, such as those informing the associations between study treatment effect and study-level characteristics—much like evaluating risk factors in the medical domain. For example, a reanalysis of three meta-epidemiological studies of 146 meta-analyses (1,346 trials) found an association between stronger treatment effect and absence of allocation concealment for subjective outcomes such as pain or quality of life, but not for objective outcomes such as mortality. Finally, empirical data in the form of surveys of the literature can document current practices and inform on their prevalence, thereby improving the description of the background context, or even the assessment of the expected impact of a recommendation (as discussed in a later section). Simply describing prevalent practices almost never constitutes sufficient support for methods recommendations.

Case studies are analogous to case reports and case series in the medical domain. These are often feasibility studies demonstrating application of a new method (see for example the paper by Berkey et al. that introduced a multivariate random effects meta-analysis method), or anecdotes that demonstrate the catastrophic implications or the infeasibility and inconsistency of a practice that should be avoided. Examples include documenting a large volume of unpublished trials of antipsychotics, that were highly contradictory to published data; and documenting the extreme fragility of study rankings and inconsistency of subgroup analyses produced by comparing 25 published scales rating the methodological quality of trials in a meta-analysis. Documentation of an undesirable event is valuable information, but it is seldom sufficient on its own to support methodological guidance. It is generally important to consider how often the undesirable event is likely to arise. Information from case studies is generally not sufficient for describing practices, documenting associations, or supporting the use of a methodology.

Finally, expert opinion,^i^ as a summary of the experts' experience and intuition, can be invoked to support methodological recommendations when no other information is available or when it is necessary to interpolate or extrapolate from existing data. We believe that much of the existing guidance is based on expert opinion.

i An expert is imprecisely defined here as someone with an understanding of the nuances of the matter at hand, and one who has a broad overview of the field.

#### On the Adequacy of the Supporting Information

Arguably, technical or mathematical problems, including those relevant to the statistical performance of methodologies, are most appropriately addressed by theoretical and technical arguments. Consider the problem addressed by R2, as defined in Table 3, where one has to choose between four methods for the meta-analysis of studies with rare events.

Table 8 summarizes the evidentiary basis of R2. An analytical answer would give the strongest possible support to the problem, but one does not exist or cannot be obtained in a practical manner. Simulation studies are the only practical way to assess the statistical performance of the four alternative choices for R2. Three simulation studies have explored the statistical properties of several methods for estimating the summary effect for meta-analyses of rare events, providing sufficient information for the comparisons in Table 3.

Table 8 Description of the evidentiary basis of R2 (“Use the Peto or the Mantel-Haenszel method for meta-analysis of rare events”)

Supporting Information | Description | Comments
Mathematical and technical arguments | No analytical answer available or practical Three simulation studies have explored questions relevant to the meta-analysis of studies with rare events. In sum, the Peto or the Mantel-Haenszel method for the odds ratio were least biased and had coverage probability closest to the nominal across simulation scenarios. | The simulation studies do not cover all possible scenarios or even all commonly used metrics. For example, they do not explore the risk ratio metric. The simulation studies are well-done, and are generalizable to the background context at hand. The simulated scenarios are applicable to real life settings.
Empirical data of large scale | We do not know of large scale empirical evidence. | Empirical evidence informs about the concordance of alternative choices in real life situations, but cannot inform about which choices are closer to the truth.
Case studies (proof of concept studies) | Isolated examples (nonexhaustive list references). | These are examples that alternative methods can yield different results.
Expert opinion | An example is reference. | Generic or irrelevant (nonmethodological) comments; no consideration of simulation data or empirical evidence.

Note: The contents of this table are not based on a systematic review of the methods literature; they are provided for exposition, and in good faith.

We are not aware of empirical studies comparing all four methods in a large number of meta-analyses including mostly studies with rare events. In any event, an empirical comparison is inadequate to answer such questions as which method minimizes statistical bias because in an empirical sample the “true” effects are unknowable. Empirical data from a survey of meta-analyses, though, can inform on how often the problem is encountered in practice, and how often the alternative methods would lead to contradictory conclusions. Finally, case reports and expert opinion are much less useful in the presence of mathematical proof, simulation or empirical studies. They can demonstrate disagreement between methods, but cannot identify the better performing one.

One might perceive that the evidentiary base of R2 is adequate (mature), because it (1) includes supporting information of the appropriate type (i.e., mathematical or technical arguments in the form of simulation studies); (2) the simulation studies are well performed; and (3) they correspond to realistic scenarios (Table 8). One might have been more reserved in the absence of well-performed simulation studies, because of the inadequate evidence provided even by large-scale empirical studies. As discussed in a later section, recommendations that are based on an adequate evidence base do not automatically rise to mandatory items or minimum standards.

Most other problems, however, cannot be addressed satisfactorily only by relying on theory or simulations, because deciding which of the alternative choices to recommend is directly informed by empirical data (i.e., at least one of the measures defined in the background context must be obtained empirically). For example, consider the problem addressed by R1 (choosing between processes for screening citations for inclusion in a systematic review). The probability of missing at least one eligible study and the resources needed for each choice must be obtained empirically. The ideal empirical study would use a paired design to compare the six alternative options in Table 2, i.e., apply all six options to a sizable number of systematic reviews. Such a study does not exist (Table 9). Instead, all-human screening has been compared with computer assisted screening in data from a case series of eight systematic reviews in clinical and molecular medicine; in another limited assessment, single screening by a human was estimated to miss between 0 and 24 percent of finally eligible studies compared with more comprehensive screening (estimation based on a capture-recapture approach).

Table 9 Description of the evidentiary basis of R1 (“Use two or more members of the review team, working independently, to screen and select studies”)

Supporting Information | Description | Comments
Mathematical and technical arguments | Not applicable. | Empirical data are necessary for ranking choices in Table 2.
Empirical data of large scale | We do not know of empirical data of large scale. | An ideal study would compare all six options in a sizable number of systematic reviews.
Case studies (proof of concept studies) | In an analysis of four screeners in a large systematic review, the estimated proportion of eligible citations missed by a single reviewer was between 0 and 24%. Computer-assisted screening has been compared with single or duplicate human screening in a small number of examples. | No study compared all six alternatives in the same samples.
Expert opinion | IOM panel and MECIR consider redundant independent screening a minimum standard and a mandatory item, respectively. | No references are provided.

IOM = Institute of Medicine; MECIR = Methodological Expectations of Cochrane Intervention Reviews

Note: The contents of this Table are not based on a systematic review of the methods literature; they are provided for exposition, and in good faith.

One might suggest that the evidentiary base of R1 is not robust, because no large-scale empirical studies exist (i.e., no supporting information of the appropriate type is available). One cannot use a mathematical or technical argument for R1, because measures to be optimized in the background context in Table 2 require specific empirical data.

### Feasibility of Implementation

This refers to the feasibility of implementing (following) the methodological recommendation in the setting of interest. Recommendations that require substantial expertise or considerable resources will, of course, be more challenging to implement for groups that do not have such expertise or resources. For example, Cochrane and EPC guidance recommend the bivariate model with binomial likelihood, or the hierarchical summary ROC (HSROC) model to synthesize diagnostic accuracy, rather than independent meta-analyses of sensitivity and specificity. The recommended methods can be implemented as hierarchical regression models or generalized linear mixed effects models, but this presupposes access to advanced statistical software, facility with statistical programming, and at least basic understanding of advanced meta-analysis. The same resource levels apply to meta-analyses of mixed treatment comparisons (network meta-analyses). Similarly, unless publicly available resources make computer-assisted screening easily accessible, three of the six options in Table 2 that include computer-assisted processes will not be widely feasible. By contrast, the recommended method in R2 for analyzing meta-analyses of studies with rare events is implemented in many widely available software tools, and requires only a very basic understanding of statistical concepts. Thus, R2 is probably quite feasible.

The feasibility of implementing the recommendation depends on the background context in which the recommendation is made. The recommendation for at least double independent screening in R1 is probably feasible for systematic reviews with adequate funding, or even for unfunded reviews with substantial organizational and other support. One might deem that implementing R1 for (most if not all) publicly funded reviews in health care is probably feasible. However, this recommendation may not be feasible as a minimum standard for systematic reviews that do not have robust funding.

### Expected Practical Impact of Implementation

The practical impact of following versus not following a methodological recommendation can be large or marginal, and can be conjectured using empirical data. For example, according to the Cochrane diagnostic test accuracy workgroup and to EPC guidance, meta-analyses of diagnostic accuracy tests should use advanced statistical methods. The rationale is that the advanced methods (bivariate syntheses of sensitivity and specificity and HSROC analysis) respect the multivariate nature of test performance metrics, allow for the nonindependence between sensitivity and specificity across studies (“threshold effect”) and also allow for between-study heterogeneity. However, in a large empirical evaluation of more than 300 meta-analyses of diagnostic test accuracy, estimates and confidence intervals for the primary metrics of sensitivity and specificity rarely differed substantially when comparing bivariate and separate univariate analyses. Comparing univariate versus multivariate meta-analysis for estimating marginal treatment effects also failed to find much benefit in the more complex multivariate approach for the major parameters of interest. However, both studies did suggest that the multivariate analyses might be beneficial in evaluating secondary parameters such as linear combinations of sensitivity and specificity. Thus, the choice between more advanced and simpler methods depends also on the measures of interest.

The expected impact of following versus not following recommendations R1 or R2 is not clear. Specifically for R1, the differential expected impact of double independent screening by reviewers over other options for redundant screening in Table 2 is not obvious. For R2, it is unclear how often conclusions would change using alternative methods.^j^

j This assessment can vary across background contexts.

### Congruence With Context-Specific Requirements

This dimension captures requirements of the background context that are not adequately captured by the other three dimensions. For example, from the perspective of the funder of systematic reviews, one goal is to produce reviews that are credible (appear to be free of conflicts of interest), generalizable, patient-centered, rigorous, timely and transparent. Additional goals may also be important to a funder, even if their importance is not immediately apparent from different perspectives. For example, it is desirable that all systematic reviews produced by a program follow standardized approaches. Therefore, a recommendation can favor one of two otherwise similar choices, on the basis of standardization across reviews. This would be less of a concern from the perspective of the consumer of the review, or of those conducting it.

For example, R1 is probably not relevant to generalizability, patient centeredness or transparency of a systematic review, but its implementation would promote the generation of reviews with other desirable attributes (most importantly, credibility and scientific rigor); and would serve program consistency (standardization) as well. One can make similar comments about R2.

## Opine on Whether a Recommendation Constitutes a Mandatory Item or a Desirable (but not Mandatory) Item (Step 4)

While users should preferably follow well-developed methodological guidance whenever possible, certain items may be more important in a resource limited setting. Those making the recommendations may wish to convey that some recommendations represent truly minimal standards or truly mandatory items, in that they are perceived essential for producing high quality systematic reviews and meta-analyses. Failure to meet such minimal standards or mandatory items would raise concerns about the validity and comprehensiveness of the review's findings and conclusions. Other recommendations may be judged to represent desirable—but not mandatory practices. For this category, most peers would agree that following the recommendation would improve the systematic review or meta-analysis, and that not following the recommendation unlikely render the review unusable.

Assuming that one would never recommend generally harmful practices, there potentially remains a third category of recommendations whose utility or necessity remains unclear. We believe that this third category should be empty because one should only make recommendations that one deems clearly beneficial given the background context at hand. This means that no methodological recommendations should be given for problems that are not well understood. As a consequence, methodological recommendations will be sparse in difficult problems where guidance in most needed, and generic rather than specific, e.g., along the lines of performing sensitivity analyses to assess robustness of results.

Those making methodological recommendations can also make comments or statements about the insufficiency of information to make a recommendation. This is analogous to the “insufficient evidence” statements (“I” statements) that the U.S. Preventive Services Task Force makes when the information is not sufficient to support a recommendation for or against an action.

A careful and balanced discussion of the aforementioned dimensions within the background context of the recommendation may help clarify the rationale for the recommendation, and may help deduce whether the recommendation is a minimum standard/mandatory item or a best practice/highly desirable item.

R1 (“use two or more members of the review team, working independently, to screen and select studies”) was considered a minimum standard in the IOM report, and a mandatory item in MECIR. Table 10 summarizes ones thoughts on R1. R1, may be a highly desirable process, but it is unclear that it “outperforms” the other five alternatives in Table 2 on the basis of the selected measures. One might prefer the following variant of R1:

R1 Use redundant screening processes rather than single screening to screen and select studies because processes that have built in a serious quality control (redundancy) are more likely to outperform single-screening-based processes. It is unclear whether IOM and MECIR considered all six alternatives in Table 2, or only two (redundant independent screening versus single screening).

Table 10 Summary of the overall strength of three example recommendations

Question/Step | R1 | R2 | R3
Phrasing | Use two or more members of the review team, working independently, to screen and select studies | Use the Peto o or the Mantel-Haenszel method rather than inverse variance weighting for meta-analysis of rare events | Use random effects models for diagnostic test meta-analysis
Is the recommendation testable? | Yes | Yes | No*
Adequacy of evidentiary basis or scientific rigor (testable statement) / face validity (nontestable statement) | See Table 9 | See Table 8 | A random rather than equal (“fixed”) effect model is more plausible. Choosing models based on data is a needless compromise if a plausible generative story can be posed.
Feasibility of implementation | No obstacles to feasibility identified | No obstacles to feasibility identified | No obstacles to feasibility identified
Expected impact of implementation | Unclear | Unclear | May result in some practical changes in conclusions because uncertainty is more fully modeled compared with equal (“fixed”) effects models
Congruence with context-specific requirements | High | High | High
Overall confidence that the recommendation is a mandatory item
IOM | High | NA | NA
MECIR | High | NA | NA

IOM = Institute of Medicine; MECIR = Methodological Expectations of Cochrane Intervention Reviews; NA = not applicable (not included in IOM or MECIR guidance)

Many peers would probably agree that R2 is a minimum standard or mandatory item, presumably because it has an adequate evidentiary support, it is feasible and congruent with the requirements of scientific rigor and credibility, and despite the fact that its practical impact is not clear. In conjunction with the above, R2 might have to be modified if summary metrics other than the odds ratio are of interest, or if additional meta-analysis methods were to be included among the alternatives.

Finally, R3 was a nontestable recommendation. As explained already, it has face validity. It is also very feasible and easy to implement. It is also likely that it can have an impact on the conclusions of systematic reviews, and it is in agreement with the desired characteristics of the background context.