# Background

Evidence-based processes such as systematic reviews and meta-analyses are increasingly used to inform health care decisions. For their findings to be trustworthy, methodologies used in evidence synthesis should be based on sound principles and theories, and supported by empirical data. Following this tenet, many entities have generated methodological guidance for performing systematic reviews, meta-analyses, and decision or economic analyses. Among them, the United States Institute of Medicine (IOM) has published 21 minimum standards (corresponding to 82 elements of performance) for publicly funded systematic reviews, and the Cochrane Collaboration has developed the 80-recommendation-strong Methodological Expectations of Cochrane Intervention Reviews (MECIR) project.

The majority of such recommendations are derived from experts' experience and knowledge of the literature, and their appreciation of the norms in the field. But wide acceptance of methodologies does not necessarily imply soundness. Indeed, many methodologies have found widespread use in evidence-based medicine without ever having been subjected to rigorous evaluation. While such standard methods and processes may appear to be sound in principle, they are often applied uncritically, without due consideration of their methodological appropriateness. Authoritative bodies, such as the Cochrane Collaboration or the Evidence-based Practice Centers (EPC) program, may then endorse popular methods, further encouraging widespread adoption. Consider the case of the funnel plot, first proposed in the mid-1980s in the social science literature as a means to detect publication bias. The Meta-analysis of Observational Studies in Epidemiology (MOOSE) group recommended the use of funnel plots “to aid in the detection of publication bias”, and numerous meta-analysts have done so, despite legitimate concerns regarding its interpretation and statistical properties. Other practices are common despite strong indications that they are not optimal, without having been recommended explicitly (at least to our knowledge). Examples include using only English-language studies in systematic reviews (e.g., documented by Dahabreh et al.), using summary quality scores for assessing methodological soundness, and using continuity corrections for meta-analyses in studies with rare events.

Similar to clinical practice guidelines, methodological recommendations for those conducting systematic reviews and meta-analyses should be transparent in their rationale, evidence base, and strength. Preferred methodologies must be identified, and the rationale for their selection and how important it is to abide by them should also be communicated to practitioners. To achieve this goal, a framework for assessing the evidence supporting the methodological recommendations for research synthesis applications would be useful. Through this framework, the details of the context in which a methodological recommendation is made could be made explicit, and for a specific methodological recommendation, the approach to assess its scientific rigor, evidence base, applicability, and feasibility could be elucidated.

This work is a foray into the problem of providing consistent and transparent methodological guidance. The aim of the proposed framework is to facilitate the presentation of the rationale for methods recommendations, and the communication of the confidence of those making the recommendation that their suggestions should be followed. The framework is not a tool for deciding which recommendation is optimal, nor a checklist for verifying that due diligence was used in coming up with a specific recommendation. It is meant strictly as a transparency and communication device. We present the framework by means of examples, most of which are inspired by actual recommendation statements. In the descriptions that follow, we assume the role of those making the methodological recommendations, irrespective of whether we agree with the content or not.