# Report Outline

There are occasions when researchers would like to combine the results of constructs that are measured on different scales, such as cognitive measures, depression, and quality of life. Combining data measuring these complex constructs can be particularly challenging, and a rigorous approach as well as specialized methods of harmonization, including statistical harmonization, are required. The use of these methods of harmonization in the conduct of systematic reviews is virtually nonexistent. In this report, we were particularly interested in combining measures of memory across studies. As there are currently no guidelines available to determine the best way to combine these types of measures, we undertook a series of projects with the underlying objective to better understand the issues around the statistical harmonization of cognitive measures.

Although there were many commonalities in cognitive measures in the data sets, they were measured using different instruments. The first study objective was to identify approaches to statistical harmonization which could be used in the context of aggregate data and/or individual participant data meta-analysis of cognitive measures. To meet this objective, two environmental scans were conducted. The first, an environmental scan of meta-analyses including cognitive measures, was conducted to identify the types of methods that have been used to combine cognition data in meta-analyses. In practice, we found that most studies either restricted their analyses to cognitive measures with a common scale or combined effect sizes across studies. None of the studies formally probed into whether the cognitive measures should be harmonized. To identify more sophisticated methods that would allow the exploration of whether the cognitive data should be combined, a second environmental scan was undertaken to assess what types of statistical harmonization methods were used in the general literature. These methods were assessed with a technical expert panel to determine their applicability harmonizing cognitive measures. The environmental scans are included in “Methods and Results: Environmental Scans to Identify Methods of Combining Cognition Data and Statistical Harmonization Methods (Objective 1).”

Of the methods identified for statistical harmonization available, it was determined that the latent variable method was promising for our problem. Multiple imputation methods also had potential, but because the focus was on summary constructs rather than individual items, it was not applicable to our situation. Before this method of harmonization could be compared with the ones traditionally used in meta-analysis, data sets that were inferentially equivalent had to be created. Like many studies of harms, the designs of the included studies were not randomized controlled trials, thus it is important to consider covariates in our analyses. The process of harmonizing the covariate information is described in “Methods and Results: Process of Preparing Data for Statistical Harmonization (Objective 2).”

Prior to conducting meta-analyses to compare the methods of statistical harmonization it was also necessary to determine whether the cognition measures were inferentially equivalent. This step was not generally taken in meta-analyses of cognition data identified in the environmental scan. Latent variable regression analysis was used to determine if the cognitive measures were measuring one consistent construct across the data sets and thus should be combinable.

The different methods for statistical harmonization in the context of a traditional meta-analysis were then compared. To create combinable measures, we used methods traditionally used to combine cognitive measures, two standardization methods, and the latent variable method identified by the environmental scan and endorsed by the Technical Expert Panel. The objective of these analyses was to examine how well the results of these statistical harmonization methods agree with each other (correlation analysis) and whether they would provide similar results if a traditional meta-analysis were undertaken. In the latent variable analysis to assess inferential equivalence, it was identified that the cognitive measures may not reflect one underlying construct, thus it was also important to see how well these different methods of statistical harmonization identified heterogeneity in the meta-analysis as well. These analyses are described in “Methods and Results: Implementing and Evaluating Three Methods of Statistical Harmonization Applied to Cognitive Measures (Objective 3).”

Finally in the discussion, we present the overall conclusions and the strengths and limitations of the study and the guidance suggested by the study results.