# References

1 Oxman AD, Clarke MJ, Stewart LA. From science to practice—Metaanalyses using individual patient data are needed. JAMA. 1995;274(10):845-6. [pmid: 7650811].
2 Riley RD, Lambert PC, Abo-Zaid G. Meta-analysis of individual participant data: Rationale, conduct, and reporting. BMJ. 2010;340:c221. [pmid: 20139215].
3 Slutsky J, Atkins D, Chang S, et al. AHRQ Series Paper 1: Comparing medical interventions: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. 2010;63(5):481-3. [pmid: 18834715].
4 Balion C, Griffith L, Strifler L, et al. Vitamin D, cognition and dementia: A meta-analysis. Clin Biochem. 2011;1166:502.
5 Annweiler C, Schott AM, Berrut G, et al. Vitamin D and ageing: neurological issues. Neuropsychobiol. 2010;62(3):139-50. [pmid: 20628264].
6 Barnard K, Colon-Emeric C. Extraskeletal effects of vitamin D in older adults: Cardiovascular disease, mortality, mood, and cognition. Am J Geriatr Pharmacother. 2010;8(1):4-33. [pmid: 20226390].
7 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1187-97. [pmid: 21477993].
8 Granda P, Blasczyk E. Data harmonization. Guidelines for Best Practice in Cross-sectional Surveys. 2nd ed. 2010:XIII.
9 Fortier I, Doiron D, Burton P, et al. Invited commentary: Consolidating data harmonization--how to obtain quality and applicability?. Am J Epidemiol. 2011;174(3):261-4. [pmid: 21749975].
10 Raina P, Santaguida P, Ismaila A, et al. Effectiveness of cholinesterase inhibitors and memantine for treating dementia: evidence review for a clinical practice guideline. Ann Intern Med. 2008;148(5):379-97. [pmid: 18316756].
11 Folstein MF, Folstein SE, McHugh PR. “Mini-mental state”. A practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res. 1975;12(3):189-98. [pmid: 1202204].
12 Mohs RC, Rosen WG, Davis KL. The Alzheimer’s disease assessment scale: An instrument for assessing treatment efficacy. Psychopharmacol Bull. 1983;19(3):448-50. [pmid: 6635122].
13 Wiener JM, Hanley RJ, Clark R, et al. Measuring the activities of daily living: Comparisons across national surveys. J Gerontol. 1990;45(6):S229-37. [pmid: 2146312].
14 Flanagan DP, Ortiz SO, Alfonso VC. Essentials of cross-battery assessment. 2nd ed. New York. Wiley. 2007.
15 Wechsler D. Administration and Scoring Manual for the Wechsler Adult Intelligence Scale. 3rd. San Antonio. The Psychological Corporation. 1997.
16 Royall DR, Chiodo LK, Polk MJ. Misclassification is likely in the assessment of mild cognitive impairment. Neuroepidemiology. 2004;23(4):185-91. [pmid: 15272221].
17 Roth M, Tym E, Mountjoy CQ, et al. CAMDEX. A standardised instrument for the diagnosis of mental disorder in the elderly with special reference to the early detection of dementia. Br J Psychiatry. 1986;149:698-709. [pmid: 3790869].
18 Teng EL, Chui HC. The Modified Mini-Mental State (3MS) examination. J Clin Psychiatry. 1987;48(8):314-8. [pmid: 3611032].
19 Wechsler D. Manual for the Wechsler Adult Intelligence Scale test—Revised. New York. Psychological Corporation. 1981.
20 Nelson HE, Wilson JR. The Revised National Adult Reading Test—Test manual Windsor. UK. NFER-Nelson. 2012.
21 Raven JC. Mill Hill Vocabulary Scale. London. 1958.
22 Cattell RB. Theory of fluid and crystallized intelligence: A critical experiment. J Educ Psychol. 1963;54:1-22.
23 Raven JC. Manual for Raven’s Progressive Matrices and Vocabulary Scales Section 1: General Overview. Harcourt Assessment. 1998.
24 Thurstone LL. Psychological implications of factor analysis. Am Psychol. 1948;3(9):402-8. [pmid: 18880205].
25 Meredith W. Measurement invariance, factor analysis and factorial invariance. Psychometrika. 1993;(4):525-43.
26 Meredith W, Horn JL. The role of factorial invariance in modelling growth and change. Collins LM, Sayer AG, editors. New methods for the analysis of change. Washington, DC. American Psychological Association. 2001:203-40.
27 Horn JL, McArdle JJ, Mason R. When is invariance not invarient: A practical scientist’s look at the ethereal concept of factor invariance. South Psychol. 1983;(4):179-88.
28 Hofer SM, Horn JL, Eber HW. A robust five-factor structure of the 16PF: Strong evidence from independent rotation and confirmatory factorial invariance procedures. Pers Indiv Differ. 1997;(2):247-69.
29 Meredith W. Notes on factorial invariance. Psychometrika. 1964;(2):177-85.
30 Muthen B. A general structural equation model with dichotomous, ordered categorical, and continuous latent variable indicators. Psychometrika. 1984;(1):115-32.
31 Takane Y, de Leeuw J. On the relationship between item response theory and factor analysis of discretized variables. Psychometrika. 1987;(3):393-408.
32 McDonald RP. Test Theory: A Unified approach. Hillsdale, NJ. Lawrence Erlbaum Associates, Inc. 1999.
33 Molenberghs G, Verbeke G. Models for discrete longitudinal data. New York. Springer. 2005.
34 Agresti A. Categorical data analysis. 2nd. Hoboken, New Jersey. John Wiley & Sons Inc. 2002.
35 Agresti A. Analysis of ordinal categorical data. 2nd. Hoboken, New Jersey. John Wiley & Sons Inc. 2010.
36 Martin M, Clare L, Altgassen AM, et al. Cognition-based interventions for healthy older people and people with mild cognitive impairment. Cochrane Database Syst Rev. 2011;1:CD006220. [pmid: 21249675].
37 Angevaren M, Aufdemkampe G, Verhaar HJ, et al. Physical activity and enhanced fitness to improve cognitive function in older people without known cognitive impairment. Cochrane Database Syst Rev. 2008;(2):CD005381. [pmid: 18425918].
38 Balint S, Czobor P, Komlosi S, et al. Attention deficit hyperactivity disorder (ADHD): Gender- and age-related differences in neurocognition. Psychol Med. 2009;39(8):1337-45. [pmid: 18713489].
39 Barth A, Winker R, Ponocny-Seliger E, et al. A meta-analysis for neurobehavioural effects due to electromagnetic field exposure emitted by GSM mobile phones. J Occup Environ Med. 2008;65(5):342-6. [pmid: 17928386].
40 Bhutta AT, Cleves MA, Casey PH, et al. Cognitive and behavioral outcomes of school-aged children who were born preterm: A meta-analysis. JAMA. 2002;288(6):728-37. [pmid: 12169077].
41 Bora E, Yucel M, Pantelis C. Cognitive endophenotypes of bipolar disorder: A meta-analysis of neuropsychological deficits in euthymic patients and their first-degree relatives. J Affect Disord. 2009;113(1–2):1-20. [pmid: 18684514].
42 Brands AMA, Biessels GJ, De Haan EHF, et al. The effects of type 1 diabetes on cognitive performance: A meta-analysis. Diabetes Care. 2005;28(3):726-35. [pmid: 15735218].
43 Campbell LK, Scaduto M, Sharp W, et al. A meta-analysis of the neurocognitive sequelae of treatment for childhood acute lymphocytic leukemia. Pediatr Blood Canc. 2007;49(1):65-73. [pmid: 16628558].
44 Eilander A, Gera T, Sachdev HS, et al. Multiple micronutrient supplementation for improving cognitive performance in children: Systematic review of randomized controlled trials. Am J Clin Nutr. 2010;91(1):115-30. [pmid: 19889823].
45 Falkingham M, Abdelhamid A, Curtis P, et al. The effects of oral iron supplementation on cognition in older children and adults: A systematic review and meta-analysis. Nutr J. Jan. 25. 2010;9:4. [doi: 10.1186/1475-2891-9-4]. [pmid: 20100340].
46 Goodman M, LaVerda N, Clarke C, et al. Neurobehavioural testing in workers occupationally exposed to lead: Systematic review and meta-analysis of publications. J Occup Environ Med. 2002;59(4):217-23. [pmid: 11934948].
47 Grant I, Gonzalez R, Carey CL, et al. Non-acute (residual) neurocognitive effects of cannabis use: A meta-analytic study. J Int Neuropsychol Soc. 2003;9(5):679-89. [pmid: 12901774].
48 Guilera G, Pino O, Gomez-Benito J, et al. Antipsychotic effects on cognition in schizophrenia: A meta-analysis of randomised controlled trials. Eur J Psychiat. 2009;23(2):77-89.
49 Hogervorst E, Bandelow S. Sex steroids to maintain cognitive function in women after the menopause: A meta-analyses of treatment trials. Maturitas. 2010;66(1):56-71. [pmid: 20202765].
50 Hogervorst E, Yaffe K, Richards M, et al. Hormone replacement therapy to maintain cognitive function in women with dementia. Cochrane Database Syst Rev. 2009;(1):CD003799. [pmid: 19160224].
51 Li H, Li N, Li B, et al. Cognitive intervention for persons with mild cognitive impairment: A meta-analysis. Ageing Res Rev. 2011;10:285-96. [pmid: 21130185].
52 Jansen CE, Miaskowski C, Dodd M, et al. A metaanalysis of studies of the effects of cancer chemotherapy on various domains of cognitive function. Cancer. 2005;104(10):2222-33. [pmid: 16206292].
53 Karsdorp PA, Everaerd W, Kindt M, et al. Psychological and cognitive functioning in children and adolescents with congenital heart disease: A meta-analysis. J Pediatr Psychol. 2007;32(5):527-41. [pmid: 17182669].
54 Krabbendam L, Arts B, Van OJ, et al. Cognitive functioning in patients with schizophrenia and bipolar disorder: A quantitative review. Schizophr Res. 2005;80(2–3):137-49. [pmid: 16183257].
55 Lethaby A, Hogervorst E, Richards M, et al. Hormone replacement therapy for cognitive function in postmenopausal women. Cochrane Database Syst Rev. 2008;(1):CD003122. [pmid: 18254016].
56 Marasco SF, Sharwood LN, Abramson MJ. No improvement in neurocognitive outcomes after off-pump versus on-pump coronary revascularisation: A meta-analysis. Eur J Cardiothorac Surg. 2008;33(6):961-70. [pmid: 18424064].
57 Metternich B, Kosch D, Kriston L, et al. The effects of nonpharmacological interventions on subjective memory complaints: A systematic review and meta-analysis. Psychother Psychosom. 2010;79(1):6-19. [pmid: 19887887].
58 McDermott LM, Ebmeier KP. A meta-analysis of depression severity and cognitive function. J Affect Disord. 2009;119(1–3):1-8. [pmid: 19428120].
59 Naguib JM, Kulinskaya E, Lomax CL, et al. Neuro-cognitive performance in children with type 1 diabetes—a meta-analysis. J Pediatr Psychol. 2009;34(3):271-82. [pmid: 18635605].
60 Nieto RG, Xavier CF. A meta-analysis of neuropsychological functioning in patients with early onset schizophrenia and pediatric bipolar disorder. J Clin Child Adolesc Psychol. 2011;40(2):266-80. [pmid: 21391023].
61 Quinn TJ, Gallacher J, Deary IJ, et al. Association between circulating hemostatic measures and dementia or cognitive impairment: systematic review and meta-analyzes. J Thromb Haemost. 2011;9(8):1475-82. [pmid: 21676170].
62 Repantis D, Schlattmann P, Laisney O, et al. Modafinil and methylphenidate for neuroenhancement in healthy individuals: A systematic review. Pharmacol Res. 2010;62(3):187-206. [pmid: 20416377].
63 Sibley BA, Etnier JL. The relationship between physical activity and cognition in children: A meta-analysis. Pediatr Exerc Sci. 2003;15(3):243-56.
64 Valentini E, Ferrara M, Presaghi F, et al. Systematic review and meta-analysis of psychomotor effects of mobile phone electromagnetic fields. J Occup Environ Med. 2010;67(10):708-16. [pmid: 20837651].
65 Voss MW, Kramer AF, Basak C, et al. Are expert athletes ‘expert’ in the cognitive laboratory? A meta-analytic review of cognition and sport expertise. Appl Cognit Psychol. 2010;24(6):812-26.
66 Wheaton P, Mathias JL, Vink R. Impact of early pharmacological treatment on cognitive and behavioral outcome after traumatic brain injury in adults: A meta-analysis. J Clin Psychopharmacol. 2009;29(5):468-77. [pmid: 19745647].
67 Woodward ND, Purdon SE, Meltzer HY, et al. A meta-analysis of cognitive change with haloperidol in clinical trials of atypical antipsychotics: Dose effects and comparison to practice effects. Schizophr Res. 2007;89(1–3):211-24. [pmid: 17059880].
68 Zhang JP, Burdick KE, Lencz T, et al. Meta-analysis of genetic variation in DTNBP1 and general cognitive ability. Biol Psychiatry. 2010;68(12):1126-33. [pmid: 21130223].
69 Granda P, Wolf C, Hadorn R. Harmonizing survey data. Harkness JA, Braun M, Edwards B, et al., editors. Survey methods in multinational, multicultural and multiregional contexts. Hoboken, NJ. John Wiley & Sons. 2010:315-32.
70 Bauer DJ, Hussong AM. Psychometric approaches for developing commensurate measures across independent studies: Traditional and new models. Psychol Methods. 2009;14(2):101-25. [pmid: 19485624].
71 Burns RA, Butterworth P, Kiely KM, et al. Multiple imputation was an efficient method for harmonizing the Mini-Mental State Examination with missing item-level data. J Clin Epidemiol. 2011;64(7):787-93. [pmid: 21292440].
72 Gorsuch R. New procedure for extension analysis in exploratory factor analysis. EPM. 1997;57(5):725-40.
73 McArdle JJ, Grimm KJ, Hamagami F, et al. Modeling life-span growth curves of cognition using longitudinal data with multiple samples and changing scales of measurement. Psychol Methods. 2009;14(2):126-49. [pmid: 19485625].
74 Minicuci N, Noale M, Bardage C, et al. Cross-national determinants of quality of life from six longitudinal studies on aging: The CLESA project. Aging Clin Exp Res. 2003;15(3):187-202. [pmid: 14582681].
75 Gross AL, Inouye SK, Rebok GW, et al. Parallel but not equivalent: Challenges and solutions for repeated assessment of cognition over time. J Clin Exp Neuropsychol. 2012;34(7):758-72. [pmid: 22540849].
76 van Buuren S, Eyres S, Tennant A, et al. Improving comparability of existing data by response conversion. J Off Stat. 2005;21(1):53-72. [pmid: 14533743].
77 Blettner M, Sauerbrei W, Schlehofer B, et al. Traditional reviews, meta-analyses and pooled analyses in epidemiology. Int J Epidemiol. 1999;28(1):1-9. [pmid: 10195657].
78 Cooper H, Patall EA. The relative benefits of meta-analysis conducted with individual participant data versus aggregated data. Psychol Methods. 2009;14(2):165-76. [pmid: 19485627].
79 Curran PJ, Hussong AM. Integrative data analysis: the simultaneous analysis of multiple data sets. Psychol Methods. 2009;14(2):81-100. [pmid: 19485623].
80 Ioannidis JPA, Rosenberg PS, Goedert JJ, et al. Commentary: Meta-analysis of individual participants’ data in genetic epidemiology. Am J Epidemiol. 2002;156(3):204-10. [pmid: 12142254].
81 Schmid CH, Landa M, Jafar TH, et al. Constructing a database of individual clinical trials for longitudinal analysis. Control Clin Trials. 2003;24(3):324-40. [pmid: 12757997].
82 Simmonds MC, Higgins JP, Stewart LA, et al. Meta-analysis of individual patient data from randomized trials: A review of methods used in practice. Clin Trials. 2005;2(3):209-17. [pmid: 16279144].
83 van der Steen JT, Kruse RL, Szafara KL, et al. Benefits and pitfalls of pooling datasets from comparable observational studies: Combining US and Dutch nursing home studies. Palliat Med. 2008;22(6):750-9. [pmid: 18715975].
84 van WC. Individual patient meta-analysis—rewards and challenges. J Clin Epidemiol. 2010;63(3):235-7. [pmid: 19595573].
85 Bennett DA. Review of analytical methods for prospective cohort studies using time to event data: Single studies and implications for meta-analysis. Stat Methods Med Res. 2003;12(4):297-319. [pmid: 12939098].
86 Friedenreich CM. Methods for pooled analyses of epidemiologic studies. Epidemiol. 1993;4(4):295-302. [pmid: 8347739].
87 Hofer SM, Piccinin AM. Integrative data analysis through coordination of measurement and analysis protocol across independent longitudinal studies. Psychol Methods. 2009;14(2):150-64. [pmid: 19485626].
88 Jones AP, Riley RD, Williamson PR, et al. Meta-analysis of individual patient data versus aggregate data from longitudinal clinical trials. Clin Trials. 2009;6(1):16-27. [pmid: 19254930].
89 Mathew T, Nordstrom K. Comparison of one-step and two-step meta-analysis models using individual patient data. Biom J. 2010;52(2):271-87. [pmid: 20349448].
90 Burgess S, Seaman S, Lawlor DA, et al. Missing data methods in Mendelian randomization studies with multiple instruments. Am J Epidemiol. 2011;174(9):1069-76. [pmid: 21965185].
91 Donegan S, Williamson P, Gamble C, et al. Indirect comparisons: A review of reporting and methodological quality. Plos One. 2010;5(11):e11054. [pmid: 21085712].
92 Peyre H, Leplege A, Coste J. Missing data methods for dealing with missing items in quality of life questionnaires. A comparison by simulation of personal mean score, full information maximum likelihood, multiple imputation, and hot deck techniques applied to the SF-36 in the French 2003 decennial health survey. Qual Life Res. 2011;20(2):287-300. [pmid: 20882358].
93 Siddique J, Crespi CM, Gibbons RD, et al. Using latent variable modeling and multiple imputation to calibrate rater bias in diagnosis assessment. Stat Med. 2011;30(2):160-74. [pmid: 21204122].
94 Spratt M, Carpenter J, Sterne JA, et al. Strategies for multiple imputation in longitudinal studies. Am J Epidemiol. 2010;172(4):478-87. [pmid: 20616200].
95 Sterne JA, White IR, Carlin JB, et al. Multiple imputation for missing data in epidemiological and clinical research: Potential and pitfalls. BMJ. 2009;338:b2393. [pmid: 19564179].
96 Crane PK, Narasimhalu K, Gibbons LE, et al. Composite scores for executive function items: demographic heterogeneity and relationships with quantitative magnetic resonance imaging. J Int Neuropsychol Soc. 2008;14(5):746-59. [pmid: 18764970].
97 Teresi JA, Ocepek-Welikson K, Kleinman M, et al. Evaluating measurement equivalence using the item response theory log-likelihood ratio (IRTLR) method to assess differential item functioning (DIF): Applications (with illustrations) to measures of physical functioning ability and general distress. Qual Life Res. 2007;16(Suppl 1):43-68. [pmid: 17484039].
98 Anstey KJ, Byles JE, Luszcz MA, et al. Cohort profile: The Dynamic Analyses to Optimize Ageing (DYNOPTA) project. Int J Epidemiol. 2010;39(1):44-51. [pmid: 19151373].
99 Bath P. The harmonisation of longitudinal data: A case study using data from cohort studies in The Netherlands and the United Kingdom. Ageing Soc. 2010;30:1419-37.
100 Beer-Borst S, Morabia A, Hercberg S, et al. Obesity and other health determinants across Europe: the EURALIM project. J Epidemiol Community Health. 2000;54(6):424-30. [pmid: 10818117].
101 Beer-Borst S, Hercberg S, Morabia A, et al. Dietary patterns in six european populations: Results from EURALIM, a collaborative European data harmonization and information campaign. Eur J Clin Nutr. 2000;54(3):253-62. [pmid: 10713749].
102 Crane PK, Narasimhalu K, Gibbons LE, et al. Item response theory facilitated cocalibrating cognitive tests and reduced bias in estimated rates of decline. J Clin Epidemiol. 2008;61(10):1018-27. [pmid: 18455909].
103 Curran PJ, Hussong AM, Cai L, et al. Pooling data from multiple longitudinal studies: the role of item response theory in integrative data analysis. Dev Psychol. 2008;44(2):365-80. [pmid: 18331129].
104 Darby S, Hill D, Deo H, et al. Residential radon and lung cancer—detailed results of a collaborative analysis of individual data on 7148 persons with lung cancer and 14 208 persons without lung cancer from 13 epidemiologic studies in Europe. Scand J Psychol. Suppl(1). 2006;32:1-83. [pmid: 16538937].
105 Fibrinogen Studies Collaboration. Correcting for multivariate measurement error by regression calibration in meta-analyses of epidemiological studies. Stat Med. 2009;28(7):1067-92. [pmid: 19222086].
106 Grimm KJ, Steele JS, Mashburn AJ, et al. Early behavioral associations of achievement trajectories. Dev Psychol. 2010;46(5):976-83. [pmid: 20822216].
107 Duncan GJ, Dowsett CJ, Claessens A, et al. School readiness and later achievement. Dev Psychol. 2007;43(6):1428-46. [pmid: 18020822].
108 Khachaturian AS, Sabbagh M. Commentary on “Developing a national strategy to prevent dementia: Leon Thal Symposium 2009.” Creating a national database for successful aging. Alzheimers Dement. 2010;6(2):132-4. [pmid: 20298973].
109 McArdle JJ, Prescott CA, Hamagami F, et al. A contemporary method for developmental-genetic analyses of age changes in intellectual abilities. Dev Neuropsychol. 1998;14(1):69-114.
110 McArdle JJ, Nesselroade JR. Using multivariate data to structure developmental change. Cohen SH, Reese HW, editors. Life-span developmental psychology: Methodological contributions. Hillsdale, NJ, England. Lawrence Erlbaum Associates, Inc. 1994:223-67.
111 McArdle JJ, Prescott CA. Contemporary models for the biometric genetic analysis of intellectual abilities. Flanagan DP, Genshaft JL, Harrison PL, editors. Contemporary intellectual assessment: Theories, tests, and issues. New York, NY, US. Guilford Press. 1997:403-36.
112 Minicuci N, Noale M, Leon Diaz EM, et al. Disability-free life expectancy: A cross-national comparison among Bulgarian, Italian, and Latin American older population. J Aging Health. 2011;23(4):629-81. [pmid: 21220352].
113 Pluijm SM, Bardage C, Nikula S, et al. A harmonized measure of activities of daily living was a reliable and valid instrument for comparing disability in older people across countries. J Clin Epidemiol. 2005;58(10):1015-23. [pmid: 16168347].
114 Ruggles S, King ML, Levison D, et al. IPUMS-International. Hist Meth. 2003;36:60-5.
115 Esteve A, Sobek M. Challenges and methods of international census harmonization. Hist Meth. 2003;36:66-79.
116 Schenker N, Raghunathan TE. Combining information from multiple surveys to enhance estimation of measures of health. Stat Med. 2007;26(8):1802-11. [pmid: 17278184].
117 Slimani N, Kaaks R, Ferrari P, et al. European Prospective Investigation into Cancer and Nutrition (EPIC) calibration study: Rationale, design and population characteristics. Public Health Nutr. 2002;5(6B):1125-45. [pmid: 12639223].
118 van Buuren S, Eyres S, Tennant A, et al. Assessing comparability of dressing disability in different countries by response conversion. Eur J Public Health. 2003;13(3 Suppl):15-9. [pmid: 14533743].
119 Hopman-Rock M, van BS, De Kleijn-De VM. Polytomous Rasch analysis as a tool for revision of the severity of disability code of the ICIDH. Disabil Rehabil. 2000;22(8):363-71. [pmid: 10896097].
120 Dorans NJ, Moses TP, Eignor DR. Principles and Practices of Test Score Equating. ETS RR-10-29. Princeton, New Jersey. Educational Testing Service. 2010.
121 Griffith LE, Shannon HS, Wells RP, et al. Individual participant data meta-analysis of mechanical workplace risk factors and low back pain. Am J Public Health. 2012;102(2):309-18. [pmid: 22390445].
122 Canadian Study of Health and Aging Working Group. Canadian study of health and aging: study methods and prevalence of dementia. CMAJ. 1994;150(6):899-913. [pmid: 8131123].
123 Tuokko H, Kristjansson E, Miller J. Neuropsychological detection of dementia: An overview of the neuropsychological component of the Canadian Study of Health and Aging. J Clin Exp Neuropsychol. 1995;17(3):352-73. [pmid: 7650099].
124 Taylor EM. The appraisal of children with cerebral deficits. Cambridge. Harvard University Press. 1959.
125 Buschke H. Cued recall in amnesia. J Clin Neuropsychol. 1984;6(4):433-40. [pmid: 6501581].
126 Spreen O, Benton A. Neurosensory centre comprehensive examination for aphasia. Victoria, B.C. University of Victoria. 1977.
127 Spreen O, Strauss E. Compendium of neuropsychological tests: Administration, norms, and commentary. 2nd ed. New York. Oxford University Press. 1998.
128 Wechsler D, Stone CP. Wechsler memory scale. New York. Psychological Corporation. 1974.
129 Benton A. Revised visual retention test: Clinical and experimental applications. 3rd ed. New York. Psychological Corporation. 1974.
130 Tuokko H, Woodward TS. Development and validation of a demographic correction system for neuropsychological measures used in the Canadian Study of Health and Aging. J Clin Exp Neuropsychol. 1996;18(4):479-616. [pmid: 8877629].
131 Van der Linden M, Adam S, Baisset-Mouly C, et al. L’evaluation de troubles de la memoire: presentation de quatre tests de memoire episodique (avec etalonnage). Marseille. Solal. 2004.
132 Belleville S, Chatelois J, Fontaine F, et al. Memoria: Batterie informatisee d’evaluation de la memoire pour Mac et PC. Montrea. Institut Universitaire de Geriatire de Montreal. 2002.
133 Bherer L, Belleville S, Peretz I. Education, age, and the Brown-Peterson technique. Dev Neuropsychol. 2001;19(3):237-51. [pmid: 11758667].
134 Rey A. Test de copie d’une figure complexe: Manuel. Paris. Les editions de centre de psychologie appliquee. 1959.
135 Regard M. Cognitive rigidity and flexibility: A neuropsychological study. University of Victoria. Canada. 1981.
136 Statistics Canada. Canadian Community Health Survey (CCHS)—Healthy aging. 2009. http://www23.statcan.gc.ca/imdb/p2SV.pl?Function=getSurvey&SDDS=5146&lang=en&db=imdb&adm=8&dis=2.
137 McComb E, Tuokko H, Brewster P, et al. Mental alternation test: Administration mode, age, and practice effects. J Clin Exp Neuropsychol. 2011;33(2):234-41. [pmid: 20865619].
138 Read DE. Neuropsychological assessment of memory in the elderly. Can J Psychol. 1987;41(2):158-74. [pmid: 3502894].
139 Findlay L, Bernier J, Tuokko H, et al. Validation of cognitive functioning categories in the Canadian Community Health Survey-Healthy Aging. Health Rep. 2010;21(4):1-16. [pmid: 21269015].
140 Butler M, Retzlaff P, Vanderploeg R. Neuropsychological test usage. Prof Psychol. 1991;14:60-76.
141 Schmidt M. Auditory verbal learning test: A handbook. Western Psychological Services. 1996.
142 Lezak MD, Howlesonn DB, Loring DW. Neuropsychological assessment. 4th ed. New York. Oxford University Press. 2004.
143 Mackler K. Test review of the Rey Auditory Verbal Learning Test: A handbook. Plake BS, Impara JC, editors. The fourteenth mental measurements yearbook. Lincoln, Nebraska. Buros Institute. 2003.
144 Backman L, Jones S, Berger AK, et al. Cognitive impairment in preclinical Alzheimer’s disease: A meta-analysis. Neuropsychology. 2005;19(4):520-31. [pmid: 16060827].
145 Tierney MC, Yao C, Kiss A. Neuropsychological tests accurately predict incident Alzheimer disease after 5 and 10 years. Neurol. 2005;64(11):1853-59. [pmid: 15955933].
146 Petersen RC, Smith GE, Waring SC, et al. Aging, memory, and mild cognitive impairment. Int Psychogeriatr. 1997;9(Suppl 1):65-9. [pmid: 9447429].
147 Schoenberg MR, Dawson KA, Duff K, et al. Test performance and classification statistics for the Rey Auditory Verbal Learning Test in selected clinical samples. Arch Clin Neuropsychol. 2006;21(7):693-703. [pmid: 16987634].
148 Feeny D, Furlong W, Boyle M, et al. Multi-attribute health status classification systems. Health Utilities Index. Pharmacoeconom. 7. 1995;5(6):490-502. [pmid: 10155335].
149 Feeny D, Furlong W, Torrance GW, et al. Multiattribute and single-attribute utility functions for the health utilities index mark 3 system 7. Med Care. 2002;40(2):113-28. [pmid: 11802084].
150 Feng Y, Bernier J, McIntosh C, et al. Validation of disability categories derived from Health Utilities Index Mark 3 scores 1. Health Rep. 2009;20(2):43-50. [pmid: 19728585].
151 Horsman J, Furlong W, Feeny D, et al. The Health Utilities Index (HUI): Concepts, measurement properties and applications. Health Qual Life Outcomes. 2003;1(54). [pmid: 14613568].
152 Kavirajan H, Hays RD, Vassar S, et al. Responsiveness and construct validity of the health utilities index in patients with dementia 3. Med Care. 2009;47(6):651-61. [pmid: 19433998].
153 Mulhern RK. Correlation of the Health Utilities Index Mark 2 cognition scale and neuropsychological functioning among survivors of childhood medulloblastoma. Int J Cancer Suppl. 1999;12:91-4. [pmid: 10679878].
154 Grober E, Buschke H. Genuine memory deficits in dementia. Dev Neuropsychol. 1987;3:13-36.
155 Macht ML, Buschke H. Age differences in cognitive effort in recall. J Gerontol. 1983;38(6):695-700. [pmid: 6630904].
156 Tuokko H, Crockett D. Cued recall and memory disorders in dementia. J Clin Exp Neuropsychol. 1989;11(2):278-94. [pmid: 2925836].
157 O’Connell ME, Tuokko H. The 12-item Buschke memory test: Appropriate for use across levels of impairment. Appl Neuropsychol. 2002;9(4):226-33. [pmid: 12584076].
158 Sarazin M, Berr C, De RJ, et al. Amnestic syndrome of the medial temporal type identifies prodromal AD: A longitudinal study. Neurol. 2007;69(19):1859-67. [pmid: 17984454].
159 Carlesimo GA, Perri R, Caltagirone C. Category cued recall following controlled encoding as a neuropsychological tool in the diagnosis of Alzheimer’s disease: A review of the evidence. Neuropsychol Rev. 2011;21(1):54-65. [pmid: 21086049].
160 Coley N, Andrieu S, Gardette V, et al. Dementia prevention: Methodological explanations for inconsistent results. Epidemiol Rev. 2008;30:35-66. [pmid: 18779228].
161 Fortier I, Burton PR, Robson PJ, et al. Quality, quantity and harmony: The DataSHaPER approach to integrating data across bioclinical studies. Int J Epidemiol. 2010;39(5):1383-93. [pmid: 20813861].
162 Fortier I, Doiron D, Little J, et al. Is rigorous retrospective harmonization possible? Application of the DataSHaPER approach across 53 large studies. Int J Epidemiol. 2011;40(5):1314-28. [pmid: 21804097].
163 DerSimonian R, Laird N. Metaanalysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
164 DerSimonian R, Kacker R. Random-effects model for meta-analysis of clinical trials: An update. Contemp Clin Trials. 2007;28(2):105-14. [pmid: 16807131].
165 Wallace BC, Schmid CH, Lau J, et al. Meta-Analyst: Software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9:80. [pmid: 19961608].
166 Fleiss JL. Statistical methods for rates and proportions. 2nd. New York. John Wiley & Sons. 1981.
167 Higgins JPT, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
168 Deeks JJ, Higgins JPT, Altman DG. Analyzing and presenting results. Higgins JPT, Green S, editors. Cochrane handbook for systematic reviews of interventions 425. Chichester, UK. Wiley. 2005;Ch 8.
169 Williamson P, Altman D, Blazeby J, et al. Driving up the quality and relevance of research through the use of agreed core outcomes. J Health Serv Res Pol. 2012;17(1):1-2. [pmid: 22294719].
170 Steenhuis RE, Ostbye T. Neuropsychological test performance of specific diagnostic groups in the Canadian Study of Health and Aging (CSHA). J Clin Exp Neuropsychol. 1995;17(5):773-85. [pmid: 8557817].
171 Bartels C, Wegrzyn M, Wiedl A, et al. Practice effects in healthy adults: A longitudinal study on frequent repetitive cognitive testing. BMC Neurosci. 2010;11:118. [pmid: 20846444].
172 Duff K. Evidence-based indicators of neuropsychological change in the individual patient: Relevant concepts and methods. Arch Clin Neuropsychol. 2012;27(3):248-61. [pmid: 22382384].
173 Salthouse TA. Influence of age on practice effects in longitudinal neurocognitive change. Neuropsychology. 2010;24(5):563-72. [pmid: 20804244].
174 Beglinger LJ, Gaydos B, Tangphao-Daniels O, et al. Practice effects and the use of alternate forms in serial neuropsychological testing. Arch Clin Neuropsychol. 2005;20(4):517-29. [pmid: 15896564].
175 Niero M, Martin M, Finger T, et al. A new approach to multicultural item generation in the development of two obesity-specific measures: the Obesity and Weight Loss Quality of Life (OWLQOL) questionnaire and the Weight-Related Symptom Measure (WRSM). Clin Ther. 2002;24(4):690-700. [pmid: 12017412].
176 Serra-Majem L, MacLean D, Ribas L, et al. Comparative analysis of nutrition data from national, household, and individual levels: Results from a WHO-CINDI collaborative project in Canada, Finland, Poland, and Spain. J Epidemiol Community Health. 2003;57(1):74-80. [pmid: 12490653].
177 Fox JP, Glas CAW. Bayesian estimation of a multilevel IRT model using Gibbs sampling. [References]. Psychometrika. 2001;(2):271-88.