# Methods and Results: Implementing and Evaluating Three Methods of Statistical Harmonization Applied to Cognitive Measures (Objective 3)

## Introduction

In the previous section we were able to conduct qualitative harmonization and develop algorithms to derive inferentially equivalent information across studies by combining categories of categorical variables or instituting common cut-points for continuous variables. Combining data on complex constructs such as cognition, however, can be particularly challenging and require other methods of harmonization, including statistical harmonization. In this case the continuous variables are all measuring an underlying construct which we assume is same across data sets, but this assumption must be tested.

To address our final objective, to evaluate different approaches to statistical harmonization when applied to cognitive measures, we undertook a number of statistical analyses. To create combinable measures we used methods identified in the environmental scans and endorsed by the Technical Expert Panel (TEP). Two standardization methods that have been commonly used to combine and compare cognitive variables across data sets and the latent variable method were used to create combinable cognition data across studies.

The pre-statistical harmonization culminated in datasets that are amenable to the creation of harmonized cognitive constructs that could be combined across studies. Prior to comparing the methods of statistical harmonization, however, we needed to determine whether our cognition measures were inferentially equivalent. Latent variable regression analysis was used to determine if the cognitive measures were measuring one construct that is consistent across the data sets. In such a setting, the cognitive measures would be combinable, but this is less clear when either the measures do not represent one construct, or whether the construct is not consistent.

A second set of analyses was used to compare the different methods for statistical harmonization in the context of a traditional meta-analysis. The objective of the second set of analyses was to examine how well the results of these statistical harmonization methods agree with each other (correlation analysis) and whether they would provide similar results if a traditional meta-analysis was undertaken.

## Methods of Statistical Harmonization

### Calculation of T-Scores

Our first standardization method was utilized in both the Canadian Study on Health and Aging (CSHA)130 and the Canadian Community Health Survey on Healthy Aging (CCHS)139 to convert raw cognitive measures to demographically-corrected standardized T-scores. T-scores are dependent on the underlying distribution of cognitive measures in each study and have been used to create norms and compare different cognitive measures on a common scale. The method for creating a T-score is a two-step process described in Tuokko, et al.130 Briefly, the T-score is created by first normalizing each cognitive test score distribution to have a mean of 10 and a standard deviation of three. Each of these test-scaled scores is then regressed separately on age, sex, and education within each study. These variables were chosen because performance on many neuropsychological measures is related to age, sex, and education142 and these measures are often normalized with the performance of a control group, characterized by age, sex, and education. Age was included as a continuous variable, but because education was measured differently across the three cohorts, we used a three-level categorical variable (low: 0 to 7 years, medium: 8 to 13 years, and high: >13 years) to represent education in our regression models. The predicted values from the regression model were then used to create a “residual” scaled score (i.e., actual scaled score—predicted scaled score) for each participant. These residual scores represent how much better or worse the individual did on the test compared with what would be predicted based on their demographic characteristics (age, education, and sex). In a second step, the residual scores were converted to T-scores for each participant using the following formula:

T - s c o r e = ( (r e s i d u a l s c o r e)/(s t a n d a r d d e v i a t i o n ( r e s i d u a l s c o r e )) ) * 10 + 50

The resulting T-scores are normally distributed and have a mean of 50 and a standard deviation of 10. T-scores can be interpreted as how an individual’s score on each cognitive measure compares to the average score of participants of the same sex and age, and with the same educational background. Because they have been adjusted for the demographic factors in their creation, the T-scores should not be related to age, education, or sex.

### Calculation of Standardized Demographic Category-Centered Scores

A second method was used to calculate study-specific scores standardized relative to a consistent group across datasets. In this case, the mean and standard deviation for a common demographically determined group that is presumed to be homogeneous with respect to the cognitive measures are used to standardize, or “center” the individual cognitive measures. Again, the demographic factors known to be associated with cognitive measures—age, education, and sex—were used to identify a homogeneous group with a sufficient sample size to provide stable estimates of the means and standard deviations of the cognitive measures. Appendix C, Table 1 displays the number and percent of participants by 5 year age categories, sex, and education level for each study. Based on these factors, there were two possible subgroups; females 70 to 74 with 8 to 13 years of education and females 75 to 79 with 8 to 13 years of education. These subgroups had similar numbers in each of the datasets. The 75 to 79 age group had a lower minimum number (n=41 in the Quebec Longitudinal Study on Nutrition and Aging [NuAge] compared with n=48 for the 70 to 74 year old subgroup), but had a larger number over all of the datasets (n=533 compared with n=488 for 70 to 74 year old subgroup). Since our goal was to identify a homogenous subgroup, we then compared the standard deviations (SD) of the cognitive measures for each of the subgroups (Appendix C Table 2). The 70 to 74 year old subgroup had a smaller SD for all measures except the Rey in the CCHS to the Canadian Longitudinal Study on Aging (CLSA) and the Buschke Total score in CSHA. Based on these data we used females 70 to 74 with 8 to 13 years of education as our reference, or “centering” group.

The mean and SD for each cognitive measure in the reference was estimated and the scaled score (C-score) was calculated for each participant as follows:

C - s c o r e = ( (r a w s c o r e - m e a n o f f e m a l e s 70 - 74 w i t h 8 - 13 y e a r s o f e d u c a t i o n)/(s t a n d a r d d e v i a t i o n o f f e m a l e s 70 - 74 w i t h 8 - 13 y e a r s o f e d u c a t i o n) )

This method retains the associations with age, sex, and education, while standardizing the scores to a common subgroup within each study. Like the T-score standardization, this method does not take into account the differences between the measurement properties of the scales.

### Calculation of Latent Variables

In this method, it is assumed that the overall test scores of a participant are influenced by a univariate continuous latent variable unique to that participant. The overall test scores are viewed as counts representing a correct number of scored test items. Conditionally on the latent variable, the overall test scores follow a binomial distribution. The performance on correctly scoring the individual test items may change even within subjects, which justifies the binomial distribution. The mathematical model is represented by:

Y_i j_ = y ∣ Z_i_ = z ~ B ( N_j_ , p_i j_ ( z ) ) Z_i_ ~ N ( 0 , τ_i_^2^ ) 1

with Y_ij_ the number of correctly scoring test items for memory test j of subject i and Z_i_ the latent variable for subject i. The latent variable Z_i_ is assumed to be normally distributed. The probability p_ij_(z) may depend on subject i through different covariates, such as age, sex, and education. It is assumed that this probability of correctly scoring an item is of the logistic type:

logit ( p_i j_ ( z ) ) = β_0 j_ + ∑_k = 1_^K^ β_k_ · x_i k_ + z , 2

with β_0j_ the intercept for test j, β_k_ ‘s the parameters for the covariates, and x_ik_ ‘s the K covariates for subject i. The standard deviation τ_i_ of the latent variable may also depend on covariates, such as age, sex, and education. It is assumed that the standard deviation has the following form:

log ( τ_i_ ) = η_0_ + ∑_k = 1_^K^ η_k_ · x_i k_ . 3

The intercept parameters in (2) are related to the difficulty of the memory test j. A larger value would indicate that the memory test would be easier to conduct, while smaller values would tell us that the corresponding memory test is harder. The ability to investigate whether memory tests would be able to discriminate between participants better than other memory tests would require a separate intercept for memory tests in formula (3), that is, in the variability of the latent variable. Estimation of discrimination parameters requires at least the use of four different memory tests. In the current model it was assumed that all memory tests would discriminate in the same way between participants.

The parameters in (2) would indicate difference in performances on the memory tests for particular subgroups of participants. For instance, it is expected that age would reduce the performance on the memory tests. The parameters in (3) on the other hand would indicate if the memory tests discriminate better for subgroups of participants, for example, whether the performance differences in memory tests are greater for males than for females (or the other way around) or whether older people would demonstrate larger differences in performance than younger people.

Model (1) with relationships (2) and (3) are related to the work of Van Buuren, et al.76 and Bauer, et al.,70 although they described procedures for individual items instead of overall test scores. Table 12 depicts the different cognitive measures calculated for each dataset. Essentially, for each of the memory measures we had the raw data, the T-score, the centered score (C-score), and the latent variable score.

Table 12 Cognition data available for analysis in CCHS-CLSA, CSHA and NuAge

Analysis Type | CCHS-CLSA | CSHA | NuAge
Within Dataset | raw-Rey | raw-Rey
Within Dataset | t-Rey | t-Rey
Within Dataset | c-Rey | c-Rey
Within Dataset | raw-HUI
Within Dataset | t-HUI
Within Dataset | c-HUI
Within Dataset | | raw-Buschke (free) | raw-Buschke (free)
Within Dataset | | t-Buschke (free) | t-Buschke (free)
Within Dataset | | c-Buschke (free) | c-Buschke (free)
Within Dataset | | raw-Buschke (total) | raw-Buschke (total)
Within Dataset | | t-Buschke (total) | t-Buschke (total)
Within Dataset | | c-Buschke (total) | c-Buschke (total)
Within Dataset | Latent-memory | Latent-Memory | Latent-Memory
Between Datasets | Harmonized latent variable [Rey] | Harmonized latent variable [Rey, Buschke (free, total)] | Harmonized latent variable [Buschke (free, total)]

CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; HUI = Health Utilities Index; n = sample size; NuAge = Quebec Longitudinal Study on Nutrition and Aging; sd = standard deviation

### Assessing the Cognitive Measures as a Single Construct

To assess if the cognitive measures included in our analyses measured a single construct, we did a number of analyses. In the cases where cognitive measures were collected in multiple studies, like the Buschke Free and Buschke Total recall in CSHA and NuAge, it can be investigated if the tests behave similarly across studies, when corrected for the covariates. This implies that the difference in two difficulty parameters β_0j_1__ and β_0j_2__ is the same across studies. To be able to compare different studies, homogeneity of the tests is required, because otherwise the different studies may not have measured the same latent variable (a form of measurement invariance). Only then is it possible to compare the parameters β_k_‘s across studies to investigate the heterogeneity between studies. This lack of homogeneity in memory tests can be investigated with a likelihood ratio test. Furthermore, a goodness-of-fit of the latent variable model is obtained by calculating Pearson’s chi-square statistic between the observed and predicted outcomes.

The value for the latent variable predicted for each subject was then compared with the T-scores. The T-scores are considered the response of the subject and the latent variable is viewed as a subject characteristic. A linear regression analysis is performed to determine the relationship between the T-scores and the latent variables. If the latent variable is measuring a single construct, one would expect a similar monotonic relationship between the latent variable and each of the T-scores. This analysis is conducted per T-score and study. The estimated regression models can be compared with respect to the estimated parameters for the latent variable.

## Results of Assessing the Cognitive Measures as a Single Construct

A latent variable model was first fitted to CCHS-CLSA, CSHA, and NuAge datasets separately. Let Y_ij_ be the number of correct words for memory test j of subject i and denote the latent variable for memory by Z_i_ for subject i. The conditional distribution of Y_ij_ given the latent variable Z_i_ = z is given by a binomial distribution with the parameters given by the maximal number of words N_j_ and the probability p_ij_(z). The latent variable Z_i_ is assumed to be normally distributed. In mathematical terms, the model is described by:

Y_i j_ = y ∣ Z_i_ = z ~ B ( N_j_ , p_i j_ ( z ) ) Z_i_ ~ N ( 0 , τ_i_^2^ ) 1

The probability p_ij_(z) may depend on subject i through the variables age, sex, and education level. It is assumed to be of the logistic type:

logit(p_ij_(z)) = β_0j_ + β_A_age + β_S_sex + β_EM_edu_medium_ + β_EH_edu_high_ + z 2

The standard deviation t_i_ of the latent variable may also depend on the three variables age, sex, and education level and is of the form:

log(τ_i_) = η_0_ + η_A_age + η_S_sex + η_EM_edu_medium_ + η_EH_edu_high_ 3

The intercepts b_0j_ for test j are related to the probability of answering the correct number of words for males with a low education and thus relates to the difficulty of the memory test. For a 70 year old woman, the values of b_S_ and 70·b_A_ need to be added to this intercept, since male is the reference group for sex and age was not centralized around the study mean. The intercept h_0_ for the standard deviation of the latent variable belongs to the same group with the same restriction to age. Note that edu_medium_ and edu_high_ were dummy variables for estimation of the effects of medium and high levels of education compared with a low level of education.

Model (1) with relationships (2) and (3) is investigated per study for its goodness-of-fit. The test scores for each subject can be predicted on the basis of the model. Pearson’s chi-square statistic is calculated between the observed and predicted outcomes. A possible lack-of-fit can be caused by many things, but one explanation is that memory is not represented by just one latent variable. This implies that the tests do not measure one univariate construct. Higher dimensional latent variable models would then be useful, but are more complicated to fit numerically, and they require three or more memory tests in each study.

The parameters for model (1) with relationships (2) and (3), together with an approximate 95% confidence interval are provided in Table 13 for all three studies.

Table 13 Estimates of the model parameters of the latent variable model

Mean Parameters | CCHS-CLSA | CSHA | NuAge
Intercept | 0.955 [0.774; 1.136] | 2.653 [2.187; 3.119] | 1.009 [−0.313; 2.332]
Effect Health Utility Index | 2.813 [2.777; 2.848] | NA | NA
Effect REY free recall | NA | −1.444 [−1.489; −1.399] | NA
Effect Buschke total recall | NA | 2.693 [2.629; 2.758] | 2.291 [2.199; 2.383]
Effect medium education | 0.201 [0.161; 0.240] | 0.049 [−0.038; 0.136] | 0.160 [−0.026; 0.346]
Effect high education | 0.356 [0.317; 0.395] | 0.176 [0.036; 0.317] | 0.357 [0.163; 0.552]
Effect sex | 0.210 [0.183;0.395] | −0.004 [−0.086; 0.078] | 0.449 [0.311; 0.588]
Effect age | −0.029 [−0.031; −0.027] | −0.033 [−0.039; −0.027] | −0.022 [−0.040; −0.005]
Variance parameters | CCHS-CLSA | CSHA | NuAge
Intercept | −3.124 [−4.295; −1.953] | −2.161 [−2.714; −1.608] | −2.263 [−4.289; −0.237]
Effect medium education | −0.063 [−0.301; 0.175] | 0.106 [0.006; 0.206] | 0.207 [−0.151; 0.565]
Effect high education | −0.010 [−0.241; 0.221] | 0.144 [−0.006; 0.293] | 0.184 [−0.186;0.555]
Effect sex | 0.148 [−0.044; 0.339] | 0.286 [0.183; 0.388] | 0.018 [−0.209; 0.244]
Effect age | 0.023 [0.008; 0.038] | 0.021 [0.014; 0.027] | 0.020 [−0.007; 0.047]

CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

From Table 13 (in the CSHA column), it follows that the Rey memory test is significantly (p<0.001) more difficult than the Buschke memory tests (p-values not shown in Table 13). The parameter for the Rey memory test is estimated negatively (−1.444), which implies that the Rey memory test is more difficult or has a lower probability of correctly recalling the words than the Buschke free memory test (which operates as the reference test). The Buschke total recall is easier than the Buschke free recall since the parameter estimate of 2.693 is positive. Apparently, subjects with a medium level of education do not significantly do better than subjects with a low education level for CSHA (p=0.271) and NuAge (p=0.091), but they do better in the CCHS study (p<0.001). High education affects the memory performance positively in all three studies (CCHS: p<0.001, CSHA: p<0.001, NuAge: p<0.001). An interesting observation is that the females in NuAge and CCHS have a better memory than the males (CCHS: p<0.001, NuAge: p<0.001), but this could not be demonstrated in the CSHA study (p=0.928). Age was negatively associated with memory in all three studies (CCHS: p<0.001, CSHA: p<0.001, NuAge: p=0.014).

The discrimination or variance of the latent variable is affected by medium education in the CSHA study (p=0.038), but this is not demonstrated in the other two studies (CCHS: p=0.604, NuAge: p=0.257). Also, sex seems to influence the variability in CSHA (p<0.001), but not in the other studies (CCHS: p=1=0.130, NuAge: p=0.879). The variance of the latent variable is affected by age in CCHS (p=0.003) and CSHA (p<0.001), but not in NuAge (p=0.139).

The latent variable model does demonstrate a strong lack-of-fit using Pearson’s goodness-of-fit statistic. This statistic was calculated over all four tests simultaneously and was equal to 22170 on 19910 degrees of freedom (p<0.001). However, the ratio of the statistic with respect to the degrees of freedom is only 1.114, which is close to one. In generalized linear models, this type of ratio would indicate an acceptable goodness-of-fit.

It is mentioned by Bauer, et al.70 that harmonizing latent variable models requires measurement invariance. Strong factorial invariance means that the mean and variance of the latent variable for each item would be the same across studies. This invariance is not met since a comparison of the parameter estimates included in the standard deviation and the mean of the latent variable across studies are not statistically similar (see the estimates and their confidence intervals in Table 13). On the other hand, the standardized latent variable can still be compared, since the differences with respect to age, sex, and education have been eliminated. It can also be viewed as heterogeneity across studies. Another aspect or form of measurement invariance is consistency or homogeneity of the memory tests. Even though the memory tests may differ across studies, it is not unrealistic that the relative complexity between the memory tests remains consistent across studies. Indeed, for comparing the relative complexity of the memory tests, the heterogeneity between studies is eliminated since the relative complexity is a comparison of the tests within subjects and not across subjects. In this report, this type of invariance can only be investigated by comparing the difference in the two Buschke tests between CSHA and NuAge. If this consistency would hold true, then both studies have implemented these tests in the same way, or they may operate in both studies in the same way, even though there may exist study heterogeneity. In this report, it means that the estimates 2.693 and 2.291 for CSHA and NuAge should be statistically the same. Homogeneity in the relative complexity of the Buschke tests was conducted with a likelihood ratio test. This test investigates if the latent variable model with the two estimates 2.693 and 2.291 is similar to the latent variable model where the two estimates can be reduced to one and the same estimate. The likelihood ratio test was determined at 49 with one degree of freedom and indicated that homogeneity in the relative complexity of the Buschke tests is rejected (p<0.001).

The univariate latent variable model demonstrated that there exists heterogeneity in the memory tests across studies in two ways. Firstly, differences in test scores between subgroups of subjects on each memory test separately (measurement invariance) are not consistent across studies, and secondly, differences between memory tests for any subgroup (relative complexity of memory tests) are also not consistent between studies.

## Results of Latent Variable Versus T-Scores and Other Variables

A comparison between the latent variable model and the other methods is needed to investigate if the methods do in principle harmonize the studies in the same way, albeit their different statistical formulations. Indeed, if the T-scores can be perfectly predicted by the latent variable, the T-scores are just another view towards the same latent variable model.

Latent variables were created using model (1) with relationships (2) and (3), with the restriction that the effect for Buschke total recall is the same for both studies (assuming homogeneity of the Buschke tests across studies). Under this model the latent variable Z_i_ for each subject can be predicted using the best linear unbiased prediction or the empirical Bayes estimator. The latent variable will be standardized with the standard deviation t_I_ to make them comparable across studies. These will be referred to as the standardized latent variables.

The standardized latent variables were compared with the T-scores per study. This was done through a graphical investigation (Figures 1 to 7) by taking the T-scores as a response variable and the latent variable as a covariate since this is considered the true value for memory behavior for individuals. The investigation shows some kind of quadratic relationship between the T-scores and the latent variable. These quadratic relationships were estimated per T-score and study. This means that the latent variable model is strongly related to the method of T-scores. However, the predictions are not perfect, which could indicate that the T-scores contain information that is not captured by the latent variable model. Furthermore, it is clear from Figures 1 to 7, that the T-score for the Health Utilities Index (HUI^®^) has a completely different relationship with the latent variable (the T-score for the HUI is found in Figure 1. The T-scores for the relationship between other measures in the latent variable are presented in Figures 2 to 7). This implies that the HUI index may not represent the same information on memory tests, which may not be surprising considering the nature of the HUI compared with the other memory tests. However we do believe that the HUI provides valuable information on the construct of memory in the latent variable model. Indeed, projecting the dots in Figure 1 onto the horizontal axis would still provide one unimodal distribution (e.g., normal distribution) for the latent variable instead of several distributions that are distinct in clear subgroups or intervals. This would not be the case when the dots would be projected onto the vertical axis. This implies that the HUI is less suitable for the use of T-scores, since it represents a more qualitative form of information, but it is suitable for the latent variable model since it extracts the relevant information from HUI for the construct of memory.

Figure 1 Scatterplot of the T-scores versus latent variable: study = CCHS-CLSA, instrument = HUI

This figure shows the relationship between the T-score based on the Health Utilities Index (HUI) and the latent variable for memory in the CCHS-CLSA dataset.

Figure 2 Scatterplot of the T-scores versus latent variable: study = CCHS-CLSA, instrument = Rey

This figure shows the relationship between the T-score based on the Rey 1st recall and the latent variable for memory in the CCHS-CLSA dataset.

Figure 3 Scatterplot of the T-scores versus latent variable: study = CSHA, instrument = Buschke Free

This figure shows the relationship between the T-score based on the Buschkehke Free recall and the latent variable for memory in the CSHA dataset.

Figure 4 Scatterplot of the T-scores versus latent variable: study = CSHA, instrument = Rey

This figure shows the relationship between the T-score based on the Rey 1st recall and the latent variable for memory in the CSHA dataset.

Figure 5 Scatterplot of the T-scores versus latent variable: study = CSHA, instrument = Buschke Total

This figure shows the relationship between the T-score based on the Buschke Total recall and the latent variable for memory in the CSHA dataset.

Figure 6 Scatterplot of the T-scores versus latent variable: study = NuAge, instrument = Buschke Free

This figure shows the relationship between the T-score based on the Buschke Free recall and the latent variable for memory in the NuAge dataset.

Figure 7 Scatterplot of the T-scores versus latent variable: study = NuAge, instrument = Buschke Total

This figure shows the relationship between the T-score based on the Buschke Total recall and the latent variable for memory in the NuAge dataset.

## Methods of Comparison of Statistical Harmonization

The objective of the second set of analyses was to examine how well the results of these statistical harmonization methods agree with each other (correlation analysis) and whether they would provide similar results if a traditional meta-analysis was undertaken. When one uses meta-analysis to estimate a combined effect from a group of similar studies, there needs to be a check that the effects found in the individual studies are similar enough that one can be confident that a combined estimate will be a meaningful description of the set of studies. In the latent variable analysis to assess inferential equivalence, however, we identified that the cognitive measures may not reflect one underlying construct, thus it was also important to see how well these different methods of statistical harmonization identified heterogeneity in the meta-analyses. One would expect the individual effect estimates among the studies to vary by chance; some variation is expected. The question is whether there is more variation than would be expected by chance alone. When this excessive variation occurs, it is called statistical heterogeneity. Based on our latent variable analysis we would expect that statistical heterogeneity would be present. In particular, we hypothesized that the Rey and the Buschke Free would be most similar as they are both measures of free recall. The Buschke Total and the HUI were slightly different measures of the memory construct. In this section we also present descriptive information on the exposure, outcome, and covariates of interest.

### Individual Dataset Analyses

We first correlated the resultant values of the constructs harmonized using different methods with each other and with the raw cognition scores using Pearson linear correlation coefficients. This analysis examined the extent to which information was lost in transforming the cognition variables. A correlation of one would imply we have not transformed our data in any way as it would be a perfect linear translation. A correlation of zero would indicate that our transformed variable had no relationship with the original scores.

We then used linear regression analysis to examine bivariate relationships between the 13 variables identified (with acceptable pairing status) with the raw and derived cognition variables. These analyses were done to determine which variables were related to memory scores, and thus could potentially explain heterogeneity if it were to be present. For each regression we report the coefficients for intercept and slope, the p-value for the slope, and the proportion of variance explained, R^2^. A multivariable model was then created for each cognitive variable using all 13 variables. Any covariate that had a statistically significant relationship with any of the cognitive measures at the p<0.05 level in at least one of the studies was included in a common set of covariates that was used to create adjusted estimates for meta-analyses (see next section).

### Combined Dataset Analysis—Aggregate Data Meta-Analysis

For each dataset, a number of summary effect estimates were calculated that were used in traditional aggregate data (AD) meta-analyses (Table 12).We chose to compare the statistically harmonized memory measures in participants reporting no or low physical activity to those reporting moderate or high levels of physical activity. Physical activity was chosen because of its known association with cognition160 and based on the results of the regression analyses from the individual dataset analyses.

A meta-analysis was conducted for each possible combination of derived cognitive measures across the three studies. Because the CCHS-CLSA included two measures (Rey [R] and HUI [H]), the CSHA included three measures (R, Buschke-Free [BF] and Buschke-Total [BT]), and NuAge included two (BF and BT), there were 12 possible combinations of cognitive measures: R-R-BF, R-R-BT, R-BF-BF, R-BF-BT, R-BT-BF, R-BT-BT, H-H-BF, H-H-BT, H-BF-BF, H-BF-BT, H-BT-BF, and H-BT-BT. Furthermore, these combinations could be analyzed using raw data, T-scores, or C-scores. The effects of using unadjusted means and means adjusted for a common set of covariates identified as potential confounders in the regression analysis were explored. For example, we started with an unadjusted effect estimate based on the raw data in each study. A mean and standard deviations were calculated for the “low” and “high” physical activity groups. A linear regression model was then used to estimate least square means and standard deviation for the “low” and “high” physical activity groups after adjusting for the common set of potential confounders. One additional analysis was done for the raw data to simulate what one would typically find if a systematic review and AD meta-analysis were conducted. Often one is limited to summary data that are not commonly adjusted across datasets. We created one additional set of AD adjusted estimates for the raw data which was the least square means adjusted for all variables that were statistically significant with that outcome within a study. For example, in CSHA, the BF AD least square means were adjusted for age, height, weight, and country of birth, while the NuAge AD BF least square means were adjusted for sex, age, height, and weight.

As the purpose of this report is to explore methods of statistical harmonization, it was assumed that these particular cognitive tests indicate the same construct and could be quantitatively combined across studies. Meta-analyses using random effects models proposed by DerSimonian and Laird163,164 for the weighted mean difference and Hedges’ g were conducted using MetaAnalyst 3.0.^165^ We used a test based on the deviations of the individual study estimates from the summary estimate of effect (the Q statistic) as our primary method to test for heterogeneity.166 To supplement this test, the I^2^, a statistic to quantify heterogeneity, was calculated to describe the proportion of the variance in the point estimate due to heterogeneity rather than sampling error.167 Although there are no strict rules for interpreting I^2^, a rough guide is that an I^2^>50 percent may represent substantial heterogeneity.168 Ten separate meta-analyses were conducted for each of the 12 combinations of derived cognitive measures, unadjusted, unadjusted using participants with complete data for all potential confounders, and adjusted means were combined using the raw data, and derived T-scores and C-scores (9 analyses). The 10^th^ analysis included the raw data adjusted for study and outcome specific covariates. For ease of comparison, the Hedges’ g analysis is presented for all cognitive measures. Meta-analysis results for the cognitive measures in their original units are included in Appendix D.

Finally, a single latent variable reflecting the memory construct was calculated for each participant of the three studies. Because there was a single latent memory construct hypothesized to underlie the cognition measures, a single meta-analysis was conducted for the unadjusted latent variable estimates. An unadjusted analysis including participants with complete data for all potential confounders and an adjusted latent variable meta-analysis were also conducted.

## Results of Comparison of Statistical Harmonization

### Individual Dataset and Descriptive Analyses

Table 14 presents the frequencies of the correct number of words identified for the four memory tests for CSHA and NuAge. The test scores are used individually to develop T-scores and C-scores, and they are used simultaneously to determine a latent variable for memory.

Table 14 Frequencies of the cognition tests in CCHS-CLSA, CSHA and NuAge

Correct Number | CCHS-CLSA (n=7,107) | | CSHA (n=1,730) | | | NuAge (n=432)
Correct Number | Health Utility | Rey Free Recall | Rey Free Recall | Buschke Free Recall | Buschke Total Recall | Buschke Free Recall | Buschke Total Recall
0 | 5,055 | 83 | 79 | 74 | 4 | 1 | 0
1 | 145 | 200 | 126 | 40 | 5 | 0 | 0
2 | 1,483 | 617 | 226 | 64 | 10 | 3 | 0
3 | 351 | 1,108 | 373 | 88 | 7 | 14 | 0
4 | 70 | 1,441 | 307 | 149 | 10 | 28 | 1
5 | 1 | 1,438 | 227 | 188 | 14 | 58 | 0
6 | NA | 1,085 | 92 | 242 | 22 | 61 | 3
7 | NA | 592 | 45 | 301 | 36 | 69 | 4
8 | NA | 324 | 18 | 248 | 46 | 64 | 4
9 | NA | 134 | 1 | 185 | 73 | 53 | 10
10 | NA | 56 | 3 | 111 | 123 | 38 | 5
11 | NA | 19 | 0 | 35 | 286 | 20 | 24
12 | NA | 8 | 0 | 5 | 1,094 | 14 | 33
13 | NA | 2 | 0 | NA | NA | 8 | 46
14 | NA | 0 | 0 | NA | NA | 1 | 81
15 | NA | 0 | 0 | NA | NA | 0 | 84
16 | NA | NA | NA | NA | NA | 0 | 137
Total | 7,105 | 7,107 | 1,497 | 1,730 | 1,730 | 432 | 432

CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; n = sample size; NA = not applicable; NuAge = Quebec Longitudinal Study on Nutrition and Aging

Table 15 displays Pearson correlation coefficients among the cognitive measures and between each cognitive measure and the latent variable. If the measures were inferentially equivalent, one would expect a high correlation among the individual measures, and a high and consistent correlation between each of the cognitive measures and the latent variable. In the CCHS, the HUI and Rey were not strongly correlated, (r=0.12), although both measures were correlated with the resulting latent variable (r=0.79 Rey and r=0.56 HUI). In both CSHA and NuAge, the Buschke Free and Buschke Total were moderately correlated (r≥0.58). The Rey and the Buschke Scores in CSHA were weakly correlated (r=0.33 (free) and r=0.27(total)). In the CSHA and NuAge, the latent variable was highly correlated with the Buschke scores (r≥0.80); in the CSHA, the correlation between the Rey and the latent variable was 0.58.

Table 15 Correlations among cognitive measures and between cognitive measures and the latent variable

Study | Variables | HUI | BUSC1 | BUSC_T | LZ
CCHS-CLSA | QREY | 0.12482 | - | - | 0.78996
CCHS-CLSA | HUI | 0.12482 | - | - | 0.56384
CSHA | QREY | | 0.33719 | 0.26896 0.67315 | 0.58046
CSHA | BUSC1 | | 0.33719 | 0.26896 0.67315 | 0.86794
CSHA | BUSC_T | | 0.33719 | 0.26896 0.67315 | 0.81743
NuAge | BUSC1 | | | 0.58398 | 0.84326
NuAge | BUSC_T | | | 0.58398 | 0.83290

BUSC1 = BUSC 1^st^ recall; BUSC_T = BUSC total recall; CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; HUI = Health Utilities Index; LZ = predictive value; NuAge = Quebec Longitudinal Study on Nutrition and Aging; QREY = REY 1^st^ recall

Table 16 provides information on the covariates that are used in the statistical analyses and how each was operationalized in the adjusted analysis. It should be noted that the T-scores and the latent variable approach only correct for age, sex, and education. Table 17 summarizes the bivariate relationships between the raw cognitive measures and the variables of interest by study. None of the variables, except for age, were statistically significant for all measures in all studies. The gender effect differed by measure. For example, in the CCHS it was significant for the Rey but not the HUI. Level of education was related to Rey and HUI, but was less strongly related to the Buschke. The relationship between the cognitive measures and anthropometric measures, weight, height, and body mass index differed within and between studies. Having a higher level of physical activity was strongly related to better cognitive measures in all studies except NuAge; however the sample size of the NuAge study was smaller than the other studies. The relationship between the chronic conditions and cognitive measures also differed among the studies. Self-reported diagnosis of diabetes and myocardial infarction were all related to the Rey and the HUI in CCHS, but high blood pressure was only significantly associated with the Rey. Appendix E includes the bivariate regression results for the T-scores and C-scores.

Table 16 Information about variables used in the meta-analyses

Variable | Levels | CCHS-CLSA (n=7107) | CSHA (n=1730) | NuAge (n=432) | p-value
Age [mean, (sd)] | Numerical | 73.2 (5.85) | 79.7 (6.96) | 73.7 (3.95) | < 0.001^a^
Height [mean, (sd)] | Male | 174.6 (7.1, n=2998) | 170.5 (7.7, n=607) | 168.5 (7.4)
Height [mean, (sd)] | Female | 160.4 (6.4, n=4073) | 157.3 (7.4, n=993) | 155.4 (5.7)
Height [mean, (sd)] | All | 166.5 (9.7, n=7,001) | 162.3 (9.9, n=1,600) | 161.5 (9.2)
Weight [mean, (sd)] | Male | 82.8 (14.3, n=2990) | 72.6 (12.7, n=622) | 80.0 (12.9)
Weight [mean, (sd)] | Female | 68.6 (13.8, n=4011) | 60.3 (12.5, n=1032) | 66.4 (12.8)
Weight [mean, (sd)] | All | 74.6 (15.7, n=7,001) | 64.9 (13.9, n=1,554) | 72.7 (14.5)
BMI | Numerical | 26.9 (4.85) | 24.6 (4.58) | 27.8 (4.58) | <0.001^a^
Sex | Male | 3004 (42.3%) | 646 (37.3%) | 200 (46.3%) | 0.001^b^
Sex | Female | 4103 (57.7%) | 1084 (62.7%) | 232 (53.7%) | 0.001^b^
Education Level | Low | 1342 (19.0%) | 841 (48.6%) | 66 (15.3%) | <0.001^b^
Education Level | Medium | 2664 (37.7%) | 619 (35.8%) | 171 (39.6%) | <0.001^b^
Education Level | High | 3055 (43.3%) | 270 (15.6%) | 195 (45.1%) | <0.001^b^
Country of Birth | Canada | 5781 (81.4%) | 1166 (67.4%) | 387 (89.6%) | <0.001^b^
Country of Birth | Other | 1324 (18.6%) | 564 (32.6%) | 45 (10.4%) | <0.001^b^
Physical Activity | Never/Low | 1938 (27.3%) | 991 (66.8%) | 493 (33.2%) | <0.001^b^
Physical Activity | Mod/High | 5169 (72.7%) | 203 (13.7%) | 341 (78.9%) | <0.001^b^
Alcohol consumption | Never | 557 (7.8%) | 1163 (77.2%) | 21 (4.86%) | <0.001^b^
Alcohol consumption | Other | 6550 (92.2%) | 344 (22.8%) | 411 (95.1%) | <0.001^b^
Occurrence Diabetes | Never | 5847 (82.3%) | 1463 (86.5%) | 392 (90.7%) | <0.001^b^
Occurrence Diabetes | Other | 1258 (17.7%) | 228 (13.5%) | 40 (9.26%) | <0.001^b^
Occurrence of High Blood Pressure | Never | 3112 (43.8%) | 947 (60.7%) | 226 (52.3%) | <0.001^b^
Occurrence of High Blood Pressure | Other | 3993 (56.2%) | 614 (39.3%) | 206 (47.7%) | <0.001^b^
Occurrence of Myocardial Infarction | Never | 6217 (87.7%) | 1402 (84.2%) | 367 (86.6%) | 0.008^b^
Occurrence of Myocardial Infarction | Other | 876 (12.4%) | 263 (15.8%) | 57 (13.4%) | 0.008^b^

CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

a Analysis of variance (between CCHS-CLSA, CSHA, and NuAge).

b Pearson’s chi-square test (between CCHS-CLSA, CSHA, and NuAge).

Table 17 Summary of relationship of raw scores for cognitive measures with variables of interest

Variable | CCHS-CLSA n=7,107 | | CSHA n=1,730 | | | NuAge n=432
Variable
Variable | Rey | HUI | Rey | BUSC1 | BUSC_T | BUSC1 | BUSC_T
Age in years (n) | 7,106 | 7,104 | 1,497 | 1,730 | 1,730 | 432 | 432
Intercept | 11.8354 | 6.4795 | 7.0990 | 13.6813 | 15.3429 | 13.3827 | 18.3016
Beta | −0.0981 | −0.0151 | −0.0463 | −0.0938 | −0.0542 | −0.0819 | −0.0578
R-square | 0.0869 | 0.0073 | 0.0332 | 0.0615 | 0.0391 | 0.0184 | 0.0113
p-value | <0.0001 | <0.0001 | <0.0001 | <0.0001 | <0.0001 | 0.0048 | 0.0269
Gender (n) | 7,106 | 7,104 | 1,497 | 1,730 | 1,730 | 432 | 432
Intercept | 4.2756 | 5.3790 | 3.2968 | 6.3050 | 11.2523 | 6.6700 | 13.6350
Beta (Ref: male) | 0.6503 | −0.0089 | 0.1876 | −0.1629 | −0.3667 | 1.2610 | 0.7572
R-square | 0.0272 | 0.00002 | 0.0027 | 0.0009 | 0.0087 | 0.0692 | 0.0310
p-value | <0.0001 | 0.7203 | 0.0442 | 0.2133 | 0.0001 | <0.0001 | 0.0002
Highest level of education (n) | 7,060 | 7,058 | 1,488 | 1,719 | 1,719 | 432 | 432
Intercept | 3.7675 | 5.2601 | 3.1001 | 6.2735 | 11.0190 | 6.9091 | 13.6515
Beta (Ref: Low (0–8)
Moderate (9–13) | 0.7843 | 0.0886 | 0.4733 | −0.1492 | −0.0015 | 0.4006 | 0.3079
High (14+) | 1.3601 | 0.1828 | 0.8941 | −0.1575 | 0.0738 | 0.6530 | 0.6384
R-square | 0.0660 | 0.004 | 0.0313 | 0.0007 | 0.0002 | 0.0084 | 0.0110
p-value | <0.0001 | <0.0001 | <0.0001 | 0.5271 | 0.8773 | 0.1632 | 0.0939
Country of birth (n) | 7,104 | 7,102 | 1,497 | 1,730 | 1,730 | 432 | 432
Intercept | 4.4698 | 5.3505 | 3.2076 | 6.0496 | 10.8972 | 7.40000 | 14.2000
Beta (Ref: other country) | 0.2235 | 0.0289 | 0.3095 | 0.2274 | 0.1860 | −0.0589 | −0.1767
R-square | 0.0020 | 0.0001 | 0.0070 | 0.0016 | 0.0021 | 0.0001 | 0.0006
p-value | 0.0002 | 0.3598 | 0.0012 | 0.0922 | 0.0571 | 0.8759 | 0.6018
Ever/current alcohol consumption (n) | 7,106 | 7,104 | 1,297 | 1,507 | 1,507 | 432 | 432
Intercept | 4.2496 | 5.3680 | 3.4443 | 6.2562 | 11.0120 | 6.0000 | 13.5714
Beta (Ref: never) | 0.4356 | 0.0063 | 0.0643 | 0.0054 | 0.1217 | 1.4161 | 0.4943
R-square | 0.0036 | 0.000003 | 0.0002 | 0.0000 | 0.0007 | 0.0162 | 0.0025
p-value | <0.0001 | 0.8907 | 0.5853 | 0.9736 | 0.2982 | 0.0080 | 0.3041
Standing height in centimeter (n) | 7,070 | 7,068 | 1,386 | 1,600 | 1,600 | 432 | 432
Intercept | 6.9217 | 5.2908 | 2.9275 | 3.9735 | 8.9286 | 12.1409 | 14.8455
Beta | −0.0136 | 0.0010 | 0.0032 | 0.0141 | 0.0132 | −0.0297 | −0.0050
R-square | 0.0046 | 0.0001 | 0.0003 | 0.0028 | 0.0048 | 0.0131 | 0.0005
p-value | <0.0001 | 0.4292 | 0.4994 | 0.0341 | 0.0055 | 0.0172 | 0.6574
Weight in Kg | 7,000 | 6,998 | 1,428 | 1,654 | 1,654 | 432 | 432
Intercept | 4.7616 | 5.3239 | 3.1631 | 4.7059 | 10.0507 | 9.1386 | 14.2068
Beta | −0.0014 | 0.0007 | 0.0040 | 0.0235 | 0.0152 | −0.0246 | −0.0023
R-square | 0.0001 | 0.0001 | 0.0010 | 0.0154 | 0.0121 | 0.0224 | 0.0002
p-value | 0.3389 | 0.3780 | 0.2332 | <0.0001 | <0.0001 | 0.0018 | 0.7502
Body mass index (n) | 6,968 | 6,966 | 1,365 | 1,576 | 1,576 | 432 | 432
Intercept | 4.3508 | 5.3571 | 3.2984 | 4.8682 | 10.3956 | 8.6985 | 14.0952
Beta | 0.0012 | 0.0007 | 0.0063 | 0.0575 | 0.0273 | −0.0486 | −0.0019
R-square | 0.0008 | 0.00001 | 0.0003 | 0.0101 | 0.0044 | 0.0087 | 0.0000
p-value | 0.0165 | 0.7784 | 0.5477 | <0.0001 | 0.0081 | 0.0529 | 0.9320
Occurrence of high blood pressure(n) | 7,104 | 7,102 | 1,358 | 1,561 | 1,561 | 432 | 432
Intercept | 4.7317 | 5.3851 | 3.4469 | 6.1542 | 10.9926 | 7.4912 | 14.0354
Beta (Ref: never) | −0.1427 | −0.0191 | −0.0563 | 0.1699 | 0.1198 | −0.3018 | 0.0131
R-square | 0.0013 | 0.00008 | 0.0002 | 0.0010 | 0.0010 | 0.0040 | 0.0000
p-value | 0.0022 | 0.4397 | 0.5650 | 0.2144 | 0.2168 | 0.1905 | 0.9494
Occurrence of diabetes (n) | 7,104 | 7,102 | 1,464 | 1,691 | 1,691 | 432 | 432
Intercept | 4.7253 | 5.3873 | 3.4269 | 6.1955 | 10.9863 | 7.3367 | 14.0077
Beta (Ref: never) | −0.4169 | −0.0746 | −0.1144 | 0.0326 | 0.1979 | 0.1133 | 0.3673
R-square | 0.0067 | 0.0008 | 0.0005 | 0.0000 | 0.0012 | 0.0002 | 0.0025
p-value | <0.0001 | 0.0202 | 0.3994 | 0.8624 | 0.1484 | 0.7758 | 0.3032
Occurrence of myocardial infarction (n) | 7,092 | 7,090 | 1,440 | 1,665 | 1,665 | 424 | 424
Intercept | 4.7196 | 5.3889 | 3.4459 | 6.2126 | 11.0057 | 7.2888 | 14.0327
Beta (Ref: never) | −0.5404 | −0.1138 | −0.1490 | 0.1258 | 0.2528 | 0.5006 | 0.1077
R-square | 0.0083 | 0.0013 | 0.0010 | 0.0003 | 0.0025 | 0.0051 | 0.0003
p-value | <0.0001 | 0.0023 | 0.2391 | 0.4740 | 0.0434 | 0.1436 | 0.7234
Categorical indicator of the participants level of physical activity using CSHA categories | 7,106 | 7,104 | 12,79 | 1,484 | 1,484 | 432 | 432
Intercept | 4.2963 | 5.298 | 3.2058 | 5.7855 | 10.8261 | 7.5870 | 14.1739
Beta (Ref: none)
Low level | 0.1992 | −0.0651 | 0.4366 | 0.6480 | 0.3512 | −0.0092 | 0.3816
Moderate or high level | 0.4578 | 0.1140 | 0.5714 | 1.1009 | 0.4862 | −0.3025 | −0.2179
R-square | 0.0082 | 0.0039 | 0.0231 | 0.0357 | 0.0141 | 0.0026 | 0.0076
p-value | <0.0001 | <0.0001 | <0.0001 | <0.0001 | <0.0001 | 0.5737 | 0.1928
Categorical indicator of the participants level of physical activity using CSHA categories (4 categories) (n) | 7,106 | 7,104 | 1,279 | 1,484 | 1,484 | 432 | 432
Intercept | 4.2963 | 5.2980 | 3.2058 | 5.7855 | 10.8261 | 7.5870 | 14.1739
Beta (Ref: none)
Low level | 0.1992 | −0.0651 | 0.4366 | 0.6480 | 0.3512 | −0.0092 | 0.3816
Moderate level | 0.3834 | 0.0975 | 0.5080 | 0.9744 | 0.3902 | −0.1623 | −0.1830
High level | 0.6909 | 0.1656 | 0.7845 | 1.5215 | 0.8054 | −0.5542 | −0.2805
R-square | 0.0115 | 0.0045 | 0.0246 | 0.0382 | 0.0169 | 0.0075 | 0.0080
p-value | <0.0001 | <0.0001 | <0.0001 | <0.0001 | <0.0001 | 0.3602 | 0.3274

BUSC1 = BUSC 1^st^ recall; BUSC_T = BUSC total recall; CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; HUI = Health Utilities Index; kg = kilograms; n= sample size; NuAge = Quebec Longitudinal Study on Nutrition and Aging

When one conducts meta-analyses using observational data, it is important to consider the impact of potential confounders on the overall analysis. If there are strong confounders and the study-specific effect estimates are not uniformly adjusted, one would expect statistical heterogeneity to be introduced. The data presented in Table 17 indicates that there were no consistently strong potential confounders among the studies.

### Combined Dataset Analysis—Aggregate Data Meta-Analysis

In evaluating the different approaches to statistical harmonization, we applied each method to our cognitive measures. We then examined the relationship between physical activity and cognition across the three datasets. In each dataset we compared the mean cognition score between two groups, low physical activity and high physical activity. In this case, the effect size is the difference in mean score between the groups.

Tables 18a to 18c provide a summary of the data comparing a high level of physical activity and a low level of physical activity included in the AD meta-analyses. For example, the average Rey score for those with a high level of physical activity in the CCHS was 4.8 (1.95) compared with 4.4 (1.91) in the low physical activity group. Table 18a displays the raw data, Table 18b includes the average values for the physical activity groups after adjustment for a common set of covariates, and Table 18c includes the average values for the activity groups after adjustment for only those statistically significant variables for that study and outcome combination. The adjusted mean differences were slightly attenuated compared with the unadjusted means, but there remained a statistically significant difference for all cognitive measures in CCHS-CLSA and CSHA. In the NuAge study, the direction of the relationship was reversed (i.e., those with lower levels of physical activity had higher cognitive scores), but the difference was not statistically significant. There was very little qualitative difference between the mean scores adjusted for the common set of covariates, compared with the difference when only statistically significant covariates were used for adjustment.

Table 18a Summary of aggregate data from CCHS-CLSA, CSHA, and NuAge studies used in traditional meta-analyses of unadjusted effect estimates for raw data

Study | Instrument | High Level of Physical Activity | | | Low Level of Physical Activity | | | Difference (95% CI )
Study | Instrument | n | Mean | SD | n | Mean | SD | Difference (95% CI )
CCHS-CLSA | Rey | 5,169 | 4.8 | 1.95 | 1,938 | 4.4 | 1.91 | 0.38 (0.28, 0.48)
CCHS-CLSA | HUI | 5,169 | 5.4 | 1.00 | 1,938 | 5.3 | 1.11 | 0.14 (0.09, 0.19)
CSHA | Rey | 449 | 3.8 | 1.85 | 830 | 3.3 | 1.72 | 0.47 (0.28, 0.68)
CSHA | Buschke Free | 493 | 6.9 | 2.45 | 991 | 5.9 | 2.71 | 0.97 (0.68, 1.25)
CSHA | Buschke Total | 493 | 11.3 | 1.52 | 991 | 10.9 | 2.07 | 0.41 (0.21, 0.62)
NuAge | Buschke Free | 341 | 7.3 | 2.38 | 91 | 7.6 | 2.45 | −0.30 (−0.85, 0.26)
NuAge | Buschke Total | 341 | 14.0 | 2.20 | 91 | 14.4 | 1.94 | −0.40 (−0,90, 0.10)

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; HUI = Health Utilities Index; n= sample size; NuAge = Quebec Longitudinal Study on Nutrition and Aging; SD = standard deviation

Table 18b Summary of aggregate data from CCHS-CLSA, CSHA, and NuAge studies used in traditional meta-analyses of effect estimates adjusted for a common set of covariates for raw data

Study | Instrument | High Level of Physical Activity | | | Low Level of Physical Activity | | | Difference (95% CI )
Study | Instrument | n | Mean | SD | n | Mean | SD | Difference (95% CI )
CCHS-CLSA | Rey | 5,045 | 4.2 | 1.81 | 1,860 | 4.0 | 1.81 | 0.24 (0.15, 0.34)
CCHS-CLSA | HUI | 5,043 | 5.4 | 1.05 | 1,860 | 5.2 | 1.05 | 0.11 (0.05, 0.17)
CSHA | Rey | 363 | 3.8 | 1.77 | 659 | 3.4 | 1.77 | 0.35 (0.12, 0.58)
CSHA | Buschke Free | 400 | 6.9 | 2.60 | 778 | 6.1 | 2.60 | 0.82 (0.50, 1.13)
CSHA | Buschke Total | 400 | 11.5 | 1.86 | 778 | 11.2 | 1.86 | 0.31 (0.09, 0.54)
NuAge | Buschke Free | 334 | 6.8 | 2.30 | 90 | 7.1 | 2.30 | −0.30 (−0.83, 0.23)
NuAge | Buschke Total | 334 | 13.9 | 2.13 | 90 | 14.2 | 2.13 | −0.35 (−0.84, 0.15)

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; HUI = Health Utilities Index; n= sample size; NuAge = Quebec Longitudinal Study on Nutrition and Aging; SD = standard deviation, adjusted for age, sex, education, BMI, country of birth, alcohol consumption, diabetes, high blood pressure and myocardial infarction

Table 18c Summary of aggregate data from CCHS-CLSA, CSHA, and NuAge studies used in traditional meta-analyses of effect estimates adjusted for a covariates that were statistically significant at p=0.05 in the original study

Study | Instrument | High Level of Physical Activity | | | Low Level of Physical Activity | | | Difference (95% CI )
Study | Instrument | n | Mean | SD | n | Mean | SD | Difference (95% CI )
CCHS-CLSA | Rey | 5,123 | 4.2 | 1.84 | 1,918 | 4.0 | 1.84 | 0.24 (0.15, 0.34)
CCHS-CLSA | HUI | 5,125 | 5.3 | 1.04 | 1,918 | 5.2 | 1.04 | 0.10 (0.05, 0.16)
CSHA | Rey | 447 | 3.8 | 1.74 | 824 | 3.4 | 1.74 | 0.36 (0.16, 0.56)
CSHA | Buschke Free | 491 | 6.8 | 2.61 | 984 | 6.1 | 2.61 | 0.76 (0.47, 1.04)
CSHA | Buschke Total | 491 | 11.4 | 1.94 | 984 | 11.1 | 1.94 | 0.28 (0.07, 0.49)
NuAge | Buschke Free | 341 | 6.7 | 2.30 | 91 | 7.0 | 2.30 | −0.34 (−0.87, 0.20)
NuAge | Buschke Total | 341 | 13.8 | 2.09 | 91 | 14.2 | 2.09 | −0.35 (−0.84, 0.13)

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; HUI = Health Utilities Index; n= sample size; NuAge = Quebec Longitudinal Study on Nutrition and Aging; SD = standard deviation, adjusted for Age, Gender, weight, height and alcohol

Tables 19a to 19l present the AD meta-analysis results for the 12 possible combinations of cognitive measures. Table 19m provides an overall summary of these results presented in Tables 19a to 19l. The overall estimated effect size was small, ranging from 0.08 to 0.18. Only two of the 60 analyses including the HUI were statistically significant. The cognitive measure combinations most likely to result in a statistically significant overall estimate were the R-R-BF and R-BT-BF (6 out of 10 comparisons). In most analyses significant heterogeneity was found. Only 23 of the 120 analyses had a p-value greater than 0.05, and five had a p-value greater than 0.10. The analyses with the least heterogeneity were associated with the R-R-BF and R-BT-BF combinations (5 of 10 analyses with p<0.05), and the H-BT-BF combination (4 of 10 analyses with p<0.05). Of the 23 analyses that did not indicate statistically significant heterogeneity at the p<0.05 level, 14 included T-scores, and all five analyses indicating a lack of heterogeneity at the p<0.10 level included T-scores. Consequently, the only four analyses with an I^2^ value less than 50 percent (indicating an “acceptable” level of homogeneity) also included T-scores. Figure 8 is an example of the forest plot where heterogeneity was not observed. The results were similar when T-scores and C-scores were combined in their natural units using weighted mean differences. The results of these analyses are summarized in Appendix D.

Table 19a Summary of traditional meta-analysis results for Rey from CCHS-CLSA and CSHA, and Buschke Free from NuAge using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.16 (0.01, 0.30) | 0.78 | 8.96 | 0.01
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.16 (0.01, 0.30) | 0.75 | 7.84 | 0.02
Raw Data | Study-Specific Statistically Significant Covariates | 0.11 (−0.02, 0.24) | 0.72 | 7.18 | 0.03
Raw Data | Common Set of Covariates | 0.11 (−0.02, 0.23) | 0.66 | 5.81 | 0.06
T-Score | Unadjusted^†^ | 0.12 (0.01, 0.23) | 0.64 | 5.5 | 0.06
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.12 (0.01, 0.22) | 0.55 | 4.47 | 0.11
T-Score | Common Set of Covariates | 0.11 (−0.02, 0.23) | 0.66 | 5.81 | 0.06
C-Score | Unadjusted | 0.16 (0.01, 0.30) | 0.78 | 8.96 | 0.01
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.16 (0.01, 0.30) | 0.75 | 7.84 | 0.02
C-Score | Common Set of Covariates | 0.11 (−0.02, 0.23) | 0.66 | 5.81 | 0.06

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19b Summary of traditional meta-analysis results for Rey from CCHS-CLSA and CSHA, and Buschke Total from NuAge using Hedges’g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.13 (−0.04, 0.30) | 0.84 | 12.20 | 0.002
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (−0.04, 0.30) | 0.82 | 10.99 | 0.004
Raw Data | Study-Specific Statistically Significant Covariates | 0.10 (−0.04, 0.24) | 0.75 | 8.14 | 0.02
Raw Data | Common Set of Covariates | 0.10 (−0.04, 0.23) | 0.72 | 7.06 | 0.03
T-Score | Unadjusted^†^ | 0.10 (−0.04, 0.23) | 0.76 | 8.34 | 0.02
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.10 (−0.04, 0.23) | 0.72 | 7.14 | 0.03
T-Score | Common Set of Covariates | 0.10 (−0.04, 0.23) | 0.72 | 7.06 | 0.03
C-Score | Unadjusted | 0.13 (−0.04, 0.30) | 0.84 | 12.20 | 0.002
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (−0.04, 0.30) | 0.82 | 10.99 | 0.004
C-Score | Common Set of Covariates | 0.10 (−0.04, 0.23) | 0.72 | 7.06 | 0.03

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19c Summary of traditional meta-analysis results for Rey from CCHS-CLSA and Buschke Free from CSHA, and NuAge using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.18 (−0.01, 0.36) | 0.88 | 16.46 | <0.001
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.18 (0.0001, 0.36) | 0.85 | 13.37 | 0.001
Raw Data | Study-Specific Statistically Significant Covariates | 0.12 (−0.04, 0.29) | 0.85 | 13.0 | 0.002
Raw Data | Common Set of Covariates | 0.13 (−0.05, 0.31) | 0.85 | 12.9 | 0.002
T-Score | Unadjusted^†^ | 0.14 (−0.03, 0.31) | 0.85 | 12.92 | 0.002
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.14 (−0.03, 0.32) | 0.82 | 11.35 | 0.003
T-Score | Common Set of Covariates | 0.14 (−0.05, 0.32) | 0.85 | 13.38 | 0.001
C-Score | Unadjusted | 0.18 (−0.01, 0.36) | 0.88 | 16.46 | <0.001
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.18 (0.0001, 0.36) | 0.85 | 13.37 | 0.001
C-Score | Common Set of Covariates | 0.13 (−0.05, 0.31) | 0.85 | 12.95 | 0.002

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19d Summary of traditional meta-analysis results for Rey from CCHS-CLSA and Buschke Free from CSHA, and Buschke Total from NuAge using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.16 (−0.05, 0.36) | 0.90 | 20.32 | <0.001
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.16 (−0.04, 0.36) | 0.88 | 16.67 | <0.001
Raw Data | Study-Specific Statistically Significant Covariates | 0.12 (−0.06, 0.29) | 0.86 | 13.98 | 0.001
Raw Data | Common Set of Covariates | 0.12 (−0.06, 0.31) | 0.86 | 14.29 | 0.001
T-Score | Unadjusted^†^ | 0.12 (−0.07, 0.31) | 0.87 | 15.93 | <0.001
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.12 (−0.07, 0.32) | 0.86 | 14.20 | 0.001
T-Score | Common Set of Covariates | 0.13 (−0.07, 0.32) | 0.86 | 14.72 | 0.001
C-Score | Unadjusted | 0.16 (−0.05, 0.36) | 0.90 | 19.88 | <0.001
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.16 (−0.04, 0.36) | 0.88 | 16.67 | <0.001
C-Score | Common Set of Covariates | 0.12 (−0.06, 0.31) | 0.86 | 14.29 | 0.001

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19e Summary of traditional meta-analysis results for Rey from CCHS-CLSA, Buschke Total from CSHA, and Buschke Free from NuAge using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.14 (0.02, 0.27) | 0.73 | 7.35 | 0.03
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.15 (0.02, 0.28) | 0.71 | 6.80 | 0.03
Raw Data | Study-Specific Statistically Significant Covariates | 0.09 (−0.01, 0.20) | 0.63 | 5.47 | 0.07
Raw Data | Common Set of Covariates | 0.10 (−0.008, 0.21) | 0.61 | 5.18 | 0.08
T-Score | Unadjusted^†^ | 0.11 (0.02, 0.19) | 0.42 | 3.44 | 0.18
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.11 (0.02, 0.20) | 0.42 | 3.44 | 0.18
T-Score | Common Set of Covariates | 0.10 (−0.01, 0.22) | 0.63 | 5.40 | 0.07
C-Score | Unadjusted | 0.14 (0.02, 0.27) | 0.73 | 7.35 | 0.03
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.15 (0.02, 0.28) | 0.71 | 6.80 | 0.03
C-Score | Common Set of Covariates | 0.10 (−0.008, 0.21) | 0.61 | 5.18 | 0.08

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

Table 19f Summary of traditional meta-analysis results for Rey from CCHS-CLSA and Buschke Total from CSHA, and NuAge using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.12 (−0.03, 0.27) | 0.81 | 10.51 | 0.005
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.12 (−0.03, 0.28) | 0.80 | 9.89 | 0.007
Raw Data | Study-Specific Statistically Significant Covariates | 0.09 (−0.03, 0.20) | 0.69 | 6.39 | 0.04
Raw Data | Common Set of Covariates | 0.09 (−0.03, 0.22) | 0.69 | 6.42 | 0.04
T-Score | Unadjusted^†^ | 0.08 (−0.04, 0.20) | 0.67 | 6.14 | 0.05
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.08 (−0.04, 0.21) | 0.70 | 6.04 | 0.05
T-Score | Common Set of Covariates | 0.09 (−0.04, 0.22) | 0.70 | 6.64 | 0.04
C-Score | Unadjusted | 0.12 (−0.03, 0.27) | 0.81 | 10.52 | 0.005
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.12 (−0.03, 0.28) | 0.80 | 9.89 | 0.007
C-Score | Common Set of Covariates | 0.09 (−0.03, 0.22) | 0.69 | 6.42 | 0.04

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19g Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA, Rey from CSHA, and Buschke Free from NuAge using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.13 (−0.02, 0.28) | 0.80 | 9.86 | 0.007
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (−0.02, 0.27) | 0.75 | 8.10 | 0.02
Raw Data | Study-Specific Statistically Significant Covariates | 0.09 (−0.04, 0.22) | 0.74 | 7.58 | 0.02
Raw Data | Common Set of Covariates | 0.09 (−0.03, 0.22) | 0.66 | 5.83 | 0.054
T-Score | Unadjusted^†^ | 0.11 (−0.01, 0.22) | 0.66 | 5.9 | 0.051
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.11 (−0.002, 0.21) | 0.57 | 4.63 | 0.099
T-Score | Common Set of Covariates | 0.09 (−0.03, 0.22) | 0.66 | 5.83 | 0.054
C-Score | Unadjusted | 0.13 (−0.02, 0.28) | 0.80 | 9.86 | 0.01
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (−0.02, 0.27) | 0.75 | 8.10 | 0.02
C-Score | Common Set of Covariates | 0.10 (−0.03, 0.22) | 0.66 | 5.83 | 0.054

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19h Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA, Rey from CSHA, and Buschke Total from NuAge using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.11 (−0.06, 0.28) | 0.84 | 12.67 | 0.002
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.11 (−0.06, 0.28) | 0.81 | 10.77 | 0.005
Raw Data | Study-Specific Statistically Significant Covariates | 0.08 (−0.06, 0.22) | 0.77 | 8.61 | 0.01
Raw Data | Common Set of Covariates | 0.08 (−0.05, 0.22) | 0.71 | 6.98 | 0.03
T-Score | Unadjusted^†^ | 0.09 (−0.06, 0.23) | 0.77 | 8.58 | 0.01
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.08 (−0.05, 0.22) | 0.72 | 7.07 | 0.03
T-Score | Common Set of Covariates | 0.08 (−0.05, 0.22) | 0.71 | 6.98 | 0.03
C-Score | Unadjusted | 0.11 (−0.06, 0.28) | 0.84 | 12.67 | 0.002
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.11 (−0.06, 0.28) | 0.81 | 10.77 | 0.005
C-Score | Common Set of Covariates | 0.08 (−0.05, 0.22) | 0.71 | 6.98 | 0.03

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19i Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA and Buschke Free from CSHA, and NuAge Using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.15 (−0.06, 0.36) | 0.90 | 20.62 | <0.001
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.15 (−0.05, 0.35) | 0.88 | 16.54 | <0.001
Raw Data | Study-Specific Statistically Significant Covariates | 0.11 (−0.08, 0.30) | 0.88 | 16.56 | <0.001
Raw Data | Common Set of Covariates | 0.12 (−0.07, 0.31) | 0.86 | 14.53 | 0.001
T-Score | Unadjusted^†^ | 0.13 (−0.05, 0.31) | 0.86 | 14.26 | 0.001
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.13 (−0.05, 0.32) | 0.84 | 12.56 | 0.002
T-Score | Common Set of Covariates | 0.12 (−0.08, 0.32) | 0.87 | 14.88 | 0.001
C-Score | Unadjusted | 0.15 (−0.06, 0.36) | 0.90 | 20.61 | <0.001
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.15 (−0.05, 0.35) | 0.88 | 16.54 | <0.001
C-Score | Common Set of Covariates | 0.12 (−0.07, 0.31) | 0.86 | 14.53 | 0.001

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19j Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA, Buschke Free from CSHA, and Buschke Total from NuAge using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.13 (−0.09, 0.35) | 0.92 | 23.61 | <0.001
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (−0.09, 0.35) | 0.90 | 19.36 | <0.001
Raw Data | Study-Specific Statistically Significant Covariates | 0.11 (−0.09, 0.30) | 0.89 | 17.66 | <0.001
Raw Data | Common Set of Covariates | 0.11 (−0.09, 0.31) | 0.87 | 15.77 | <0.001
T-Score | Unadjusted^†^ | 0.11 (−0.09, 0.31) | 0.88 | 17.08 | <0.001
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.11 (−0.09, 0.31) | 0.87 | 15.21 | <0.001
T-Score | Common Set of Covariates | 0.11 (−0.09, 0.32) | 0.88 | 16.11 | <0.001
C-Score | Unadjusted | 0.13 (−0.09, 0.35) | 0.92 | 23.61 | <0.001
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (−0.09, 0.35) | 0.90 | 19.36 | <0.001
C-Score | Common Set of Covariates | 0.11 (−0.09, 0.31) | 0.87 | 15.77 | <0.001

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19k Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA, Buschke Total from CSHA, and Buschke Free from NuAge using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.12 (−0.004, 0.24) | 0.72 | 7.01 | 0.03
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.12 (−0.001, 0.24) | 0.70 | 6.04 | 0.049
Raw Data | Study-Specific Statistically Significant Covariates | 0.09 (−0.03, 0.21) | 0.68 | 6.30 | 0.04
Raw Data | Common Set of Covariates | 0.09 (−0.02, 0.20) | 0.60 | 4.97 | 0.08
T-Score | Unadjusted^†^ | 0.10 (0.02, 0.17) | 0.38 | 3,21 | 0.20
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.10 (0.01, 0.18) | 0.36 | 3.14 | 0.21
T-Score | Common Set of Covariates | 0.09 (−0.03, 0.21) | 0.62 | 5.25 | 0.07
C-Score | Unadjusted | 0.12 (−0.004, 0.24) | 0.72 | 7.01 | 0.03
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.12 (−0.001, 0.24) | 0.67 | 6.04 | 0.049
C-Score | Common Set of Covariates | 0.09 (−0.02, 0.20) | 0.60 | 4.97 | 0.08

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19l Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA and Buschke Total from CSHA, and NuAge using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data | Unadjusted | 0.10 (−0.05, 0.24) | 0.80 | 9.76 | 0.008
Raw Data | Unadjusted (Including Participants with Complete Data for Covariates) | 0.10 (−0.05, 0.24) | 0.77 | 8.65 | 0.01
Raw Data | Study-Specific Statistically Significant Covariates | 0.08 (−0.05, 0.21) | 0.73 | 7.32 | 0.03
Raw Data | Common Set of Covariates | 0.08 (−0.04, 0.20) | 0.67 | 6.10 | 0.047
T-Score | Unadjusted^†^ | 0.07 (−0.04, 0.19) | 0.65 | 5.72 | 0.06
T-Score | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.07 (−0.05, 0.19) | 0.64 | 5.51 | 0.06
T-Score | Common Set of Covariates | 0.08 (−0.05, 0.21) | 0.69 | 6.39 | 0.04
C-Score | Unadjusted | 0.10 (−0.05, 0.24) | 0.80 | 9.76 | 0.008
C-Score | Unadjusted (Including Participants with Complete Data for Covariates) | 0.10 (−0.05, 0.24) | 0.77 | 8.65 | 0.01
C-Score | Common Set of Covariates | 0.08 (−0.04, 0.20) | 0.67 | 6.10 | 0.047

CCHS = Canadian Community Health Survey; CI = confidence interval; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

* All Q Statistics have 2 degrees of freedom.

† T-Scores minimally adjusted for age, sex and education level.

Table 19m Summary of Tables 19a through 19l on traditional meta-analysis results

Selection of Memory Tests | Type of Outcome | Ranges of Values From the Analysis With Different Selections of Covariates
Selection of Memory Tests | Type of Outcome
Selection of Memory Tests | Type of Outcome | Effect Size | I^2^ | Q | p-value
CCHS:REY | Raw | 0.11—0.16 | 0.66—0.78 | 5.81—8.96 | 0.01—0.06
CSHA:REY | T-score | 0.11—0.12 | 0.55—0.66 | 4.47—5.81 | 0.06—0.11
NuAge: Buschke Free | C-score | 0.11—0.16 | 0.66—0.78 | 5.81—8.96 | 0.01—0.06
CCHS:REY | Raw | 0.10—0.13 | 0.72—0.84 | 7.06—12.20 | 0.002—0.03
CSHA:REY | T-score | 0.10—0.10 | 0.72—0.76 | 7.06—8.34 | 0.02—0.03
NuAge: Buschke Total | C-score | 0.10—0.13 | 0.72—0.84 | 7.06—12.20 | 0.002—0.03
CCHS:REY | Raw | 0.12—0.18 | 0.85–0.88 | 12.9—16.46 | <0.001—0.002
CSHA:Buschke Free | T-score | 0.14—0.14 | 0.82—0.85 | 11.35—13.38 | 0.001—0.002
NuAge: Buschke Free | C-score | 0.13—0.18 | 0.85—0.88 | 12.95—16.46 | <0.001—0.002
CCHS:REY | Raw | 0.12—0.16 | 0.86—0.90 | 13.98—20.32 | <0.001—0.001
CSHA:Buschke Free | T-score | 0.12—0.13 | 0.86—0.87 | 14.20—15.93 | <0.001—0.001
NuAge: Buschke Total | C-score | 0.12—0.16 | 0.86—0.90 | 14.29—19.88 | <0.001—0.001
CCHS:REY | Raw | 0.09—0.15 | 0.61—0.73 | 5.18—7.35 | 0.03—0.08
CSHA:Buschke Total | T-score | 0.10—0.11 | 0.42—0.63 | 3.44—5.40 | 0.07—0.18
NuAge: Buschke Free | C-score | 0.10—0.15 | 0.61—0.73 | 5.18—7.35 | 0.03—0.08
CCHS:REY | Raw | 0.09—0.12 | 0.69—0.81 | 6.39—10.51 | 0.005—0.04
CSHA:Buschke Total | T-score | 0.08—0.09 | 0.67—0.70 | 6.04—6.64 | 0.04—0.05
NuAge: Buschke Total | C-score | 0.09—0.12 | 0.69—0.81 | 6.42—10.52 | 0.005—0.04
CCHS:HUI | Raw | 0.09—0.13 | 0.66—0.80 | 5.83—9.86 | 0.007—0.054
CSHA:REY | T-score | 0.09—0.11 | 0.57—0.66 | 4.63—5.9 | 0.051—0.10
NuAge: Buschke Free | C-score | 0.10—0.13 | 0.66—0.80 | 5.83—9.86 | 0.01—0.054
CCHS:HUI | Raw | 0.08—0.11 | 0.71—0.84 | 6.98—12.67 | 0.002—0.03
CSHA:REY | T-score | 0.08—0.09 | 0.71—0.77 | 6.98—8.58 | 0.01—0.03
NuAge: Buschke Total | C-score | 0.08—0.11 | 0.71—0.84 | 6.98—12.67 | 0.002—0.03
CCHS:HUI | Raw | 0.11—0.15 | 0.86—0.90 | 14.53—20.62 | <0.001—0.001
CSHA:Buschke Free | T-score | 0.12—0.13 | 0.84—0.87 | 12.56—14.88 | 0.001—0.002
NuAge: Buschke Free | C-score | 0.12—0.15 | 0.86—0.90 | 14.53—20.61 | <0.001—0.001
CCHS:HUI | Raw | 0.11—0.13 | 0.87—0.92 | 15.77—23.61 | <0.001
CSHA:Buschke Free | T-score | 0.11—0.11 | 0.87—0.88 | 15.21—17.08 | <0.001
NuAge: Buschke Total | C-score | 0.11—0.13 | 0.87—0.92 | 15.77—23.61 | <0.001
CCHS:HUI | Raw | 0.09—0.12 | 0.60—0.72 | 4.97—7.01 | 0.03—0.08
CSHA:Buschke Total | T-score | 0.09—0.10 | 0.36—0.62 | 3.14—5.25 | 0.07—0.21
NuAge: Buschke Free | C-score | 0.09—0.12 | 0.60—0.72 | 4.97—7.01 | 0.03—0.08
CCHS:HIU | Raw | 0.08—0.10 | 0.67—0.80 | 6.10—9.76 | 0.008—0.047
CSHA:Buschke Total | T-score | 0.07—0.08 | 0.64—0.69 | 5.51—6.39 | 0.04—0.06
NuAge: Buschke Total | C-score | 0.08—0.10 | 0.67—0.80 | 6.10—9.76 | 0.008—0.047

Figure 8 Forest plot representing the difference in the mean T-scores for cognition between high and low physical activity groups using the Rey in CCHS, Buschke Total in CSHA, and the Buschke Free in NuAge

The p-value_Heterogeneity_=0.18 and the I^2^ =42%

This figure shows the forest plot of the difference in the mean t-scores for cognition between high and low physical activity groups using the Rey in CCHS, Buschkehke Total in CSHA and the Buschkehke Free in NuAge.with 95% confidence interval (95% CI). Overall random effects mean difference is 0.106 (95% CI: 0.022, 0.189).

Table 20 includes the AD meta-analysis results in which a single latent variable representing the common cognitive construct is measured for individuals within each study. These are equivalent to the AD analyses presented in tables 19a to 19l, but because all of the cognitive measures were combined in a single latent variable, only one set of analyses is presented. Like the T-score, the latent variable is minimally adjusted for age, sex, and education level. Because the cognitive measures were not inferentially equivalent, one would expect significant statistical heterogeneity when we forced the creation of a single latent variable. The average effect size of 0.13 was not qualitatively different based on adjusted for additional variables of interest. In each case, the I^2^ and the p-value of the Q statistic indicated significant heterogeneity.

Table 20 Summary of traditional meta-analysis results for a common variable constructed from the latent variable analysis using Hedges’ g

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Latent Variable—Weighted Mean Difference | Unadjusted^†^ | 0.13 (−0.03, 0.29) | 0.83 | 12.01 | 0.002
Latent Variable—Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.13 (−0.03, 0.29) | 0.81 | 10.37 | 0.006
Latent Variable—Weighted Mean Difference | Common Set of Covariates | 0.13 (−0.04, 0.30) | 0.83 | 11.98 | 0.002

CI = confidence interval

* All Q Statistics have 2 degrees of freedom.

† Latent variable minimally adjusted for age, sex and education level.

## Results of Sensitivity Analyses

This section describes some additional statistical analyses to investigate the robustness of some of our results described in previous sections. This section is organized by different subsections, each subsection relates to a specific topic of the results.

### Language Differences and Living Conditions in Latent Variable Model

Buschke total recall is a memory test that is easier than the Buschke free recall memory test. The differences in difficulty were however not consistent for the two Canadian studies CSHA and NuAge. The measurement invariance principle was questioned. Reasons for this inconsistency in the memory tests could have different origins, but two explanations could come from the sample differences between CSHA and NuAge. The latter study contained only French speaking community-dwelling participants while CSHA had English and French speaking participants in combination with community-dwelling and institutionalized people. Therefore, the inconsistency in Buschke memory tests was investigated for French speaking community-dwelling participants only.

In the full analysis of the latent variable model that is reported in Table 13, the difference in difficulty for Buschke total recall between CSHA and NuAge was estimated at 0.40 (2.69−2.29). In our sensitivity analysis on French speaking community dwelling participants this estimated difference changed to 0.41, which is not smaller than in the full analysis. The likelihood ratio test again gives a p-value smaller than 0.001. This implies that the inconsistency in the Buschke memory tests between CSHA and NuAge could not be explained by language differences nor by differences in the living conditions of participants (institutionalized or not).

The latent variable model in the full analysis could have incorporated an effect for language differences and differences in living conditions (institutionalized or not) on the memory performance and the discrimination of the memory tests. For CSHA, this analysis demonstrates that language did not significantly affect the average performance on the memory tests (p=0.055), but institutionalized participants performed worse (p<0.001) than community-dwelling participants. Furthermore, the memory tests did discriminate somewhat better between French speaking participants and English speaking participants (p=0.005), which means that French speaking participants demonstrated a larger variation in memory test scores than English speaking participants. The institutionalized participants showed substantially more variation in the performance of the memory tests than community-dwelling participants (p<0.001).

A comparison of the estimated latent variables for participants that were based on the inclusion and exclusion of language and living circumstances did not demonstrate a large difference. Indeed, Pearson’s correlation coefficient was estimated at 0.979 (95% CI, 0.976 to 0.980), which indicates that the latent variable is minimally affected by language and living conditions. This implies that the results from our selected latent variable model are considered sufficient. It should be mentioned that a correction for living circumstances would be somewhat arbitrary since several participants may not be institutionalized at the start of CSHA, but they could have been institutionalized only a few months later. Furthermore, institutionalization is also related to age, for which we already corrected.

### IPD Meta-Analysis

The meta-analysis on the raw scores, T-scores, C-scores, and latent variables in Tables 18 through 20 were concerned with a traditional meta-analysis on the aggregate data. Since the individual participant data were available, we could have done an IPD meta-analysis as well. Therefore, we provided this analysis as a sensitivity analysis to see how much it would provide similar results to the AD meta-analysis.

For the IPD meta-analysis, we unified raw scores into 0 to 100 scales so that scores can be comparable between tests and between studies. We conducted two-stage (Appendix F) and one-stage (Appendix G) IPD meta-analyses. The two-stage approach is similar to our original approach as summary effect estimates are calculated for each study. An overall effect estimate is calculated as a weighted average of the study-specific estimates. We also used a one-stage meta-analysis on all data simultaneously using a linear mixed model. This model incorporates the effect of physical activity with the outcome variable, unadjusted or adjusted for covariates, and a random intercept for studies to model possible heterogeneity across studies.

The results of the two-stage and one-stage IPD meta-analyses are summarized in Appendix F and Appendix G. A similar summary table was provided for the AD meta-analysis discussed in previous section to be able to compare the two approaches. The results using these models were very similar to each other. Comparing the coefficients for physical activity between the IPD and AD meta-analyses demonstrates that the AD meta-analyses give wider confidence intervals than the IPD meta-analyses.