# Methods and Results: Process of Preparing Data for Statistical Harmonization (Objective 2)

## Introduction

The statistical pooling of cognitive data is a complex process and requires many steps before it can be undertaken. Before we could compare our chosen methods of statistical harmonization we had to create data sets that were inferentially equivalent. To meet our second objective of implementing the steps of a retrospective harmonization in a specific example of combining cognitive data from three studies, we undertook the process of qualitative harmonization.

In this section, the process of pre-statistical harmonization of the cognition data is described. This includes the selection of data sets, identification of relevant cognitive domains and instruments, the identification of other variables of interest (e.g., variables associated with cognition) and potential confounding variables (e.g., sex, age, and education), the qualitative harmonization of the noncognitive variables, and preparation of data for statistical harmonization before pooling of cognitive variables can be undertaken.

Qualitative harmonization is used in this section whenever we deemed that inferentially equivalent variables could be created using processing algorithms. For example, age can be grouped into standard categories across studies. In qualitative harmonization, a process is first undertaken to determine what data can be validly combined across studies. If it is determined that data can be combined across studies then processing algorithms are created and implemented on data collected by each individual study to produce a standard (i.e., common format) set of variables. Most of these transformations involve grouping continuous values or grouping different response categories across studies into standard categories. It is important to mention that qualitative harmonization can only be applied to simple constructs (e.g., quantity of cigarettes smoked, marital status). It is not applicable to harmonize more complex measures such as different rating scales across studies.

## Prestatistical Harmonization Methods

### Identification of Potential Datasets

Acquiring individual participant data (IPD) from research studies is a time consuming activity.121 Collecting and assembling IPD from studies of work-related mechanical exposures and low back pain, for example, took nearly 3 years.121 To identify candidate data sets, we balanced feasibility to acquire data in a timely fashion with the availability of sufficient cognitive constructs to conduct a statistical harmonization. We proposed including data sets that were accessible to study co-investigators, included complex cognitive measures of which at least some were overlapping among the data sets, and contained data on additional variables of interest and confounding variables. After discussion with the Technical Expert Panel (TEP), individual level data from three Canadian studies were obtained: the Canadian Study on Health and Aging (CSHA), the Canadian Community Health Survey on Healthy Aging (CCHS), and the Quebec Longitudinal Study on Nutrition and Aging (NuAge). A brief description of each of these data sets follows. Although we have included data sets collected within a single country, the studies are all population-based. Canada has two official languages and is culturally diverse such that one may find the type of heterogeneity usually expected between countries.

#### Canadian Study on Health and Aging

The CSHA is a national, population-based study of dementia in Canadian adults aged 65 or older (Table 7).122 In the first wave of the CSHA in 1991 (CSHA-1), face-to-face interviews were conducted with 10,263 older adults across Canada: 9,008 were living in the community and 1,255 were living in institutions. The 10,263 comprised representative random samples of people aged 65 or over, drawn in 39 urban centers and nearby rural areas in the 10 Canadian provinces.

Table 7 Characteristics of CSHA, CCHS-CLSA, and NuAge cohorts

Characteristic | CSHA | CCHS-CLSA | NuAge
Study Design | 10 year Longitudinal Cohort with follow-up at 5 and 10 years | Cross-Sectional | 5-year Longitudinal Cohort with yearly follow-up
Period of Recruitment | Feb 1991–May 1992 | Dec 2008–Nov 2009 | Jan 2004–April 2005
Sample Size at Baseline | 10,263 (9,008 community-dwelling; 1,255 institutionalized) | 20,087 (full CCHS sample 32,005) | 1,793
Inclusion Criteria | Community-dwelling and residents of institutions aged 65 and older residing in Canada. All participants scoring below 78/100 on the Modified Mini-Mental State Examination and a subsample of persons scoring 78 or greater were invited to attend the clinical component of the CSHA (total n=2,339). Those who could not complete the 3MS (n=59) were sent for clinical evaluation. All participants were required to be fluent in either English or French. | Community-dwelling people aged 45 years and over living in one of the ten Canadian provinces. The content of the CCHS-Healthy Aging was developed collaboratively by Statistics Canada and researchers from the CLSA. As part of the Statistics Canada-CLSA collaboration, CCHS participants were asked whether their survey data could be shared with the CLSA. The CCHS-CLSA sample includes data from CCHS participants between the ages of 45–85 who agreed to share their data with the CLSA | Community-dwelling men and women 67–84 years old living in the regions of Montreal, Laval and Sherbrooke in Quebec, Canada who spoke French or English, were free of disabilities in activities of daily living, without cognitive impairment, able to walk one block or to climb one flight of stairs without rest and willing to commit to a 5-year study period
Exclusion Criteria | | Individuals living on Indian Reserves and on Crown Lands, institutional residents, full-time members of the Canadian Forces, residents of certain remote regions | Those who had heart failure ≥ class II, chronic obstructive pulmonary disease requiring oxygen therapy or oral steroids, inflammatory digestive diseases or cancer treated either by radiation therapy, chemotherapy or surgery in the past 5 years
Sampling Frame | The community sampling frame used the computerized records of the provincial universal health insurance plans, except in the province of Ontario where an aggregated list based on election and other municipal records was used. Age-stratified random samples were drawn in each sampling area, following an optimum allocation procedure. The institutional sampling frame included nursing homes and chronic care facilities. Institutions were stratified by size and random samples of people aged 65 or over were drawn from them. | The CCHS—Healthy Aging used the 2006 Census as its sampling frame. All dwellings within the 10 Canadian provinces containing at least one household member aged 45 and over were included in the sampling population. A two-step strategy was used to allocate the sample to the provinces. First, 125 sample units based on groups of census area dissemination blocks were allocated to each domain of interest (10 age/sex groups) in each province. Second, the remaining units were allocated to the provinces using a power-allocation method
Response Rate | 85.7% | 74.4% | 58.6%
Subset Included in Current Study | n=1,730 participants with full neuropsychological battery | n=7,107 participant 65 years and older who completed the CCHS cognition module | n=432 participating in the nutrition quality and cognitive decline sub-study

3MS = Modified Mini Mental State Exam; CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging

In CSHA-1, a cognitive screening test, the Modified Mini-Mental State Exam (3MS), was administered to all community residents. Community-dwelling residents who scored less than 78 on the 3MS, plus a sample of people who scored 78 or above, were invited to undergo the clinical assessment. The clinical assessment was also conducted for participants who could not complete the 3MS, and all those living in institutions. At the clinical assessment, a nurse re-administered the 3MS. Participants scoring 50 or more on the 3MS were administered a standardized neuropsychological assessment by a trained psychometrician.123 The Neuropsychological Assessment included tools to measure the following domains of cognition: memory, abstract thinking, executive function, judgment, aphasia, amnesia, and construction (Table 8).19,124–129 These tests were shown to accurately predict incident Alzheimer’s disease after 5 and 10 years.130 Our study includes the 1,730 CSHA participants who had complete data for the neuropsychological battery at CSHA-1.

Table 8 Neuropsychological measures/tests in CSHA, CCHS-CLSA and NuAge

Domain | Test/Task | CSHA | CCHS-CLSA | NuAge
Memory | Buschke Cued Recall | • | | •
Memory | Wechsler Memory Scale: Information Subtest | •
Memory | Rey Auditory-Verbal Learning | • | •
Memory | Benton Visual Retention Test-Revised | •
Memory | Working Memory | •
Memory | Brown-Peterson Task | | | •
Memory | Rey & Taylor recall | | | •
Memory | Health Utilities Index Memory/Thinking Attribute | | •
Abstract thinking | WAIS—R Similarities Test (short form) | •
Executive functioning | WAIS-R Digit Symbol Sub-test | • | | •
Executive functioning | Animal Naming (semantic fluency) | • | •
Executive functioning | Mental Alternation Test | | •
Executive functioning | Stroop Task | | | •
Judgment | WAIS-R Comprehension (short form) | •
Aphasia | Tokens Test | •
Aphasia | Word Fluency | •
Agnosia | Buschke Visual Identification | •
Construction | WAIS-R Block Design (short form) | •
Construction | Rey & Taylor copy test | | | •

CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; NuAge = Quebec Longitudinal Study on Nutrition and Aging; WAIS-R = Wechsler Adult Intelligence Scale-Revised

#### Quebec Longitudinal Study on Nutrition and Aging

NuAge is a 5-year observational study of 1,793 men and women aged 68–82 years in good general health at recruitment (Table 7). Community-dwelling men and women, living in the regions of Montreal, Laval, and Sherbrooke in Quebec, Canada, were included if they spoke French or English, were free of disabilities in activities of daily living, had no cognitive impairment (Modified Mini-Mental State Examination [3MS] score, >79), were able to walk one block or climb one flight of stairs without rest, and were willing to commit to a 5-year study period. Those who had heart failure greater than or equal to Class 2, chronic obstructive pulmonary disease requiring oxygen therapy or oral steroids, inflammatory digestive diseases, or cancer treated by radiation therapy, chemotherapy, or surgery in the past 5 years were excluded. Face-to-face recruitment interviews were through 2003 to 2005.

NuAge includes many sub-studies on some relevant, complex research problems, one of which was to examine the effects of nutrition quality on cognitive decline. In 2006 to 2007 and 2008 to 2009, a neuropsychological battery was administered to a subset of 464 NuAge participants. Only francophone participants with a 3MS above the age-adjusted cut-off for risk of dementia at the third NuAge visit were recruited. Additional exclusion criteria for this sub-study included head trauma resulting in unconsciousness, stroke leading to hospitalization, cardiac arrest with resuscitation, epilepsy, subdural hematoma, sub-arachnoid hemorrhage, brain tumor or metastasis, central nervous system infection (e.g., meningitis), Guillain-Barré syndrome, multiple sclerosis, and toxicity (e.g., CO2 or methanol intoxication). The battery included instruments to measure memory, psychomotor speed, and executive function (Table 8).19,131–135 This study includes data from the 432 respondents of the first administration of the neuropsychological battery in 2006 to 2007 with complete cognition data.

#### Canadian Community Health Survey on Healthy Aging

The CCHS-Healthy Aging includes community-dwelling people aged 45 years and over living in the 10 Canadian provinces (Table 7).136 Excluded from the sample were residents of the three territories, persons living on Indian reserves, Crown lands, in institutions, full-time members of the Canadian Forces, and residents of some remote regions. Data collection took place in participants’ homes from December 1, 2008 through November 30, 2009 using computer-assisted personal interviewing. The content of the CCHS-Healthy Aging was developed collaboratively by Statistics Canada and researchers from the Canadian Longitudinal Study on Aging (CLSA). As part of the Statistics Canada-CLSA collaboration, CCHS participants were asked whether their survey data could be shared with the CLSA. This article includes data from CCHS participants who were between the ages of 45 and 85 years and who agreed to share their data with the CLSA, henceforth referred to as the CCHS-CLSA sample.

The cognition module was administered in English and French to consenting, nonproxy respondents. CCHS questionnaires included four cognitive instruments to measure memory and executive function (Table 8).127,137,138 The categorization of levels of cognitive functioning in the Canadian household population aged 45 or older based on these data has been validated.139 Standardized scores for these instruments were found to be related to self-reported general and mental health status, memory, and problem-solving ability, activities of daily living, life satisfaction, loneliness, depression, and chronic conditions in cross-sectional data. To make the study populations more comparable, the analyses included 7,107 CCHS-CLSA participants who were 65 or more years old and had complete data for the cognition module.

### Identification of Relevant Cognitive Domains and Instruments

As described previously, there are several domains of cognition and instruments that have very different applications and properties. Constructs most often combined in meta-analyses of cognitive measures include general cognitive tests, such as the 3MS. Although the general tests can often be used for screening, tools that measure specific domains of cognition are required to measure specific aspects of cognitive function such as memory and executive function.

Table 8 displays the cognitive domains and specific instruments used in the CSHA, CCHS and NuAge. The underlying assumption of meta-analysis is that one is combining comparable information across studies. As such, an a priori decision was made to restrict the analyses to instruments that measured the same cognitive domain. As many of the statistical harmonization methods require overlapping items, instruments that were used in at least two of the three studies were chosen. The idea was that even if no items are common to all studies, the studies can be “chained” together. For example, if item sets A and B are available in study 1, item sets B and C are available in study 2 and item sets C and D are available in study 3. These studies are chained by A-B-B-C-C-D. To meet these requirements, we chose to focus our statistical harmonization analyses on the memory domain and the specific instruments including the Rey Auditory Verbal Learning Test (RAVLT) and the Buschke Cued Recall Procedure (BCRP).

Commonly, a meta-analyst has access to only the summary measures for most studies. For example, the RAVLT is a summation of correctly recalled words from a list of 15. If one had access to the complete data set, they might also be able to analyze each of the 15 nouns separately. Summary measures were used for this project as this best represents the type of data one would be including in a Comparative Effectiveness Review. One additional requirement for latent variable analysis, however, is that more than one variable per study is required for convergence, similar to item response theory models. In both the CSHA and NuAge, multiple cognitive measures met this criterion. The only measure that met all of the criteria in the CCHS was the RAVLT. To help identify and attain convergence of our model, we also included the Health Utilities Index Memory/Thinking attribute which is a measure of memory, but is not included in another study. The Health Utilities Index (HUI^®^) is an indirect measure of memory, but will still contain information on the memory construct and thus is informative for our latent variable model.

#### The Rey Auditory Verbal Learning Test

The RAVLT124 was used to measure short-term memory in the CSHA and the CCHS. The RAVLT is a 15-item word learning test that assesses both learning and retention. A participant is read a list of words and asked to listen carefully. The participant is then asked to recall as many words as they can in any order. There are generally a number of immediate trials and then a delayed trial. In the CSHA there were five trials and a delay; in the CCHS, there was one trial and a delay.

The RAVLT is one of the most widely used neuropsychological test instruments140 and extensive normative data is available for both the English and French versions.127,141 The RAVLT has good test-retest reliability (0.51 ≤ r ≤0.86),142 though reliability as low as 0.12 has been reported,143 and has been shown to be extremely sensitive in detecting early cognitive decline.144,145 Overall, patients diagnosed with probable Alzheimer’s disease recalled fewer words than normal controls. Similarly, those with mild cognitive impairments also recalled significantly fewer words than normal controls.146 Schoenberg and colleagues147 reported respectable classification accuracy on the delayed recall trial using a cut-off of z-scores <1.5 SD and clinician diagnosis for Alzheimer’s disease as the criteria (sensitivity = 82.9 percent, specificity = 82.8 percent, positive predictive value [PPV] = 86.2 percent, and negative predictive value = 78.9 percent).

#### The Health Utilities Index Cognition Attributes

HUI is a generic, preference-scored, comprehensive system for measuring health status and health-related quality of life, which produces utility scores.148 The HUI Mark III assesses functional health in eight domains: vision, hearing, speech, ambulation, dexterity, emotion, pain and cognition.149,150 The HUI has been used in many settings and has been shown to have strong validity and reliability,151 even in patients with dementia.152 The cognition subscale is derived from two questions regarding usual ability to remember things and to think and solve day-to-day problems. The HUI cognition subscale has been shown to be correlated with other measures of Intelligence Quotient and achievement in children,153 as well as with the RAVLT and other neuropsychological memory tests in adults.139

#### The Buschke Cued Recall Procedure

The BCRP tests memory under conditions of free recall and cued recall. The particularity of the test is that it includes a preliminary stage that ensures appropriate encoding of the material. Subjects are shown a picture sheet with four images of objects belonging to four different categories. They are asked to point out and name the object in each category. For example, “Which one is a piece of clothing?” Following this, the sheet is taken away and the examiner ensures that the items have been properly encoded by asking immediate cued recall of each item. This is continued for all items on the list to ensure that the information has been learned and effectively encoded. After a distracter task, the subject is asked to recall the items that were viewed (free recall). The interviewer then provides cues for items missed during free recall. The free and cued recall procedures are repeated over a number of trials. A delayed recall trial is administered after a break. The CSHA used English and French versions of the 12 item Buschke memory test (BMT)125 and NuAge used a French version of the Free and Cued Selective Reminding Test (FCSR), 16 item test adapted from Grober and Buschke.154 In both cases, the scores are simply the number of items recalled spontaneously or in response to cues. Both CSHA and NuAge included three immediate trials and one delayed trial.

The BMT and FCSR were designed to minimize apparent memory deficits that would be confounded with problems in attention or encoding154 by ensuring that all items have been appropriately encoded and by providing cues during learning and retrieval to lessen the cognitive effort required by older adults.155 Among measures of memory functioning, the free recall measure was the best predictor of functional impairment in older persons with suspected memory disorders.156 All measures from the Buschke memory test have been shown to differentiate among individuals with various levels of cognitive impairment.157 The 16-item version has also been shown to be able to distinguish patients with mild cognitive impairment (MCI) who converted to Alzheimer’s disease from MCI nonconverters.158 In seven studies comparing individuals with Alzheimer’s disease and healthy controls, both free recall and total recall have shown to have high sensitivity (62 to 100 percent) and specificity (94 to 100 percent).159

### Identification of Other Variables of Interest and Potential Confounding Variables

We wanted to examine how our methods of statistical harmonization impact the relationship between the cognition construct with other variables. To do this, a set of variables was identified for which there is a strong understanding of the underlying relationship with cognition. These variables included sociodemographic and lifestyle factors (age, sex, education, income, country of birth, physical activity, smoking status, alcohol consumption) and anthropometric and health conditions (height, weight, body mass index, hip circumferences, heart rate, diastolic and systolic blood pressure, and self-reported diagnosis of high blood pressure, stroke, diabetes, myocardial infarction, and family history of high blood pressure, stroke, diabetes, myocardial infarction). These variables were selected based on the demonstrated relationship with cognition in the literature160 and endorsed by the TEP.

The DataSHaPER (DataSchema and Harmonization Platform for Epidemiological Research; www.datashaper.org) approach to qualitatively harmonize variables of interest was employed.161,162 Using this approach, a set of variables targeted for a harmonization project is first defined. Such a set of variables is called a DataSchema. A priori rules are then defined for each variable of a DataSchema and used to formally determine if the information collected in a given study can be used to generate a given DataSchema variable. This step of the process therefore establishes what data can be validly combined across studies. The process of applying the rules and assessing the compatibility of variables with the DataSchema is called pairing. Selection and definition of DataSchema variables, rule creation, and pairing are based on protocols involving iteration between domain experts, research assistants, and a validation panel. The compatibility of each study’s data and each variable in a DataSchema is assessed on a three-level scale of matching quality: “complete,” “partial,” or ‘impossible” match. Table 9 describes the elements required for each level of compatibility. All variables of interest that are a “complete” or “partial” match to the DataSchema were included.

Table 9 Classification of the level of compatibility between assessment items and DataSchema variables

Class^*^ | Description
Complete | According to the pairing rules, the meaning, format or standard operating procedures used for collection of the assessment items allow construction of the variable as defined.
Partial | According to the pairing rules, the meaning, format or standard operating procedures used for collection of the assessment items allow the construction of the variable as defined, but with an unavoidable loss of information. This class includes two subcategories: Proximate: if the only reason for the classification as partial is because categories are used to collect information for a DataSchema variable that is defined as continuous. Tentative: whenever a variable is classified as partial for any other reason.
Impossible | If no relevant information is collected (Impossible Not Covered) or, based on the pairing rules, insufficient information exists to construct the variable as defined (Impossible Covered).

* In certain instances, a DataSchema variable is not pertinent in the context of a particular study (e.g., the ‘occurrence of prostate cancer’ variable in the context of a study recruiting only women). In such cases, the variable is classified as “not applicable” for that study.

## Results—Prestatistical Harmonization

Table 10 presents a description of the 34 variables of interests and the pairing results for the three studies. Family history of chronic conditions was not collected in any of the studies. Of the remaining variables, there were complete matches in all studies for 10 targeted variables: age, sex, household income, country of birth, height, weight, body mass index, occurrence of diabetes, and level of physical activity (3 categories and 4 categories). There were complete or partial matches across the 3 participating studies for 3 variables: alcohol consumption, occurrence of high blood pressure, and myocardial infarction. Each of the education variables had at least one impossible match; however a simplified three-level categorical variable indicating the number of years of education (low (0 to 8 years), medium (9 to 13 years), and high (>13 years) could be derived in all data sets. Because income was only available for a subset of the CSHA participants, it was not included in the analyses. Stroke was measured in the three datasets, but the definition was sufficiently different (stroke vs. all cerebrovascular event) that it could not be used in the analyses.

Table 10 Variable description and results of pairing for CSHA, CCHS-CLSA, and NuAge

Candidate Variable | Variable Description | CSHA | CCHS-CLSA | NuAge
Age | Participant’s age at recruitment self reported by the participant. | CM | CM | CM
Sex | Gender of the participant. | CM | CM | CM
Highest Level of Education | Highest level of education completed by the participant. | CM | CM | IM
Number of Years Education | Number of years of education | CM | IM | CM
Household Income | Average current annual income, before taxes, of the participant’s entire household. | PM | CM | CM
Household Income Categorical | Average current annual income, before taxes, of the participant’s entire household [underlined: based on CSHA categories]. | CM | CM | CM
Country of Birth | Country where the participant was born. | CM | CM | CM
Ever Smoked Cigarettes | Indicator of whether the participant has ever smoked cigarettes. | PM | CM | IM
Current Cigarette Smoker | Indicator of whether the participant currently smokes cigarettes. | IM | CM | PM
Current Quantity of Cigarettes Smoked | Current average number of cigarettes smoked per week. | IM | CM | PM
Ever Alcohol Consumption | Indicator of whether the participant has ever consumed alcohol. | PM | CM | IM
Current Use Alcohol | Indicator of whether the participant currently consumes alcohol. | IM | CM | CM
Current of Ever Use of Alcohol | Indicator of whether the participant currently or ever consumes alcohol. | PM | CM | PM
Standing Height | The vertical measurement or distance from the foot to the head of the participant when he/she is standing. | CM | CM | CM
Weight | Weight of the participant. | CM | CM | CM
Body Mass Index | Weight (in kg) divided by height (in m) squared. Body mass index = (Weight)/(Standing height * 0.01)^2^ | CM | CM | CM
Hip Circumference | Measured distance around hips. | IM | IM | CM
Waist Circumference | Measured distance around waist. | IM | IM | CM
Heart Rate at Rest | Number of heart beats per minute measured at rest. | IM | IM | CM
Diastolic Blood Pressure at Rest | Diastolic blood pressure measured at rest. | CM | IM | CM
Systolic Blood Pressure at Rest | Systolic blood pressure measured at rest. | CM | IM | CM
Occurrence of High Blood Pressure | Occurrence of high blood pressure at any point during the life of the participant. | CM | CM | PM
Current Treatment for High Blood Pressure | Indicator of whether the participant is currently treated for high blood pressure. | CM | CM | IM
Occurrence of Stroke | Occurrence of stroke at any point during the life of the participant. | CM | CM | IM
Occurrence of Diabetes | Occurrence of diabetes at any point during the life of the participant. | CM | CM | CM
Occurrence of Myocardial Infarction | Occurrence of myocardial infarction at any point during the life of the participant | CM | CM | PM
Family History of High Blood Pressure | Occurrence of high blood pressure amongst members of the biological family of the participant (mother, father, siblings and children). | IM | IM | IM
Family History of Stroke | Occurrence of stroke amongst members of the biological family of the participant (mother, father, siblings and children). | IM | IM | IM
Family History of Diabetes | Occurrence of diabetes amongst members of the biological family of the participant (mother, father, siblings and children). | IM | IM | IM
Family History of Myocardial Infarction | Occurrence of myocardial infarction amongst members of the biological family of the participant (mother, father, siblings and children). | IM | IM | IM
Level of Physical Activity | Categorical indicator of the participant’s level of physical activity. Based on IPAQ scoring protocol (https://sites.google.com/site/theipaq/scoring-protocol). | IM | CM | CM
Total physical activity | Quantitative indicator of global physical activity in metabolic equivalent (MET)-minutes per week. Based on IPAQ scoring protocol (https://sites.google.com/site/theipaq/scoring-protocol) | IM | CM | CM
Level of Physical Activity (CSHA-based—ordinal) | Categorical indicator of the participant’s level of physical activity using CSHA categories (ordinal; 3 categories) | CM | CM | CM
Level of Physical Activity (CSHA-based -binary) | Categorical indicator of the participant’s level of physical activity using CSHA categories (binary) | CM | CM | CM

CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CM = complete match; CSHA = Canadian Study of Health and Aging; IM = impossible match; IPAQ = International Physical Activity Questionnaire; kg = kilograms; m = meters; NuAge = Quebec Longitudinal Study on Nutrition and Aging; PM = partial match

Sociodemographic and health-related characteristics of participants of the CSHA, CCHS-CLSA, and NuAge included in the analyses are presented in Table 11. The average age of the CCHS-CLSA participants (73.2 years) and NuAge participants (73.7 years) was less than that of CSHA participants (79.7 years). The CSHA participants tended to have a lower level of education and income (adjusted to 1992) compared with the CCHS-CLSA and NuAge participants. Income, as previously mentioned, was only available for a subset of CSHA participants and was not included in any analyses. As well, fewer participants reported being born in Canada in CSHA. The CCHS-CLSA and NuAge more often reported being a current alcohol drinker than the CSHA participants; however, there were some differences in the way the question was asked across studies (Appendix B). More CSHA participants reported a low level of physical activity compared with CCHS-CLSA and NuAge. The CSHA participants also reported a lower level of physical activity and alcohol consumption. The CCHS-CLSA participants reported high blood pressure and diabetes more often than CSHA or NuAge participants.

Table 11 Demographic and health-related characteristics of CSHA, CCHS-CLSA, and NuAge at baseline in participants with cognition data

| CCHS-CLSA (n=7,107) | CSHA (n=1,730) | NuAge (n=432)
Age [mean (sd)] | 73.2 (5.9) | 79.7 (7.0) | 73.7 (4.0)
Age Group (n, %)
65–74 | 4,162 (58.6) | 367 (21.2) | 265 (61.3)
75–85 | 2,945 (41.4) | 976 (56.4) | 167 (38.7)
>85 | | 387 (22.4) | -
Sex (n, % Female) | 4,103 (57.7) | 1,084 (62.7) | 232 (53.7)
Highest Level of Education
Low (0–8) | 1,342 (19.0) | 841 (48.9) | 66 (15.3)
Medium (9–13) | 2,664 (37.7) | 619 (35.8) | 171 (39.6)
High (14+) | 3,055 (43.3) | 270 (15.6) | 195 (45.1)
Household Income (n, %)
<$10k | 360 (2.22) | 39 (6.9) | 3 (0.7)
$10k to $14,999 | 712 (4.40) | 108 (19.1) | 20 (4.6)
$15k to $19,999 | 1,000 (6.18) | 35 (6.2) | 19 (4.4)
$20k to $29,999 | 1926 (11.90) | 66 (11.6) | 66 (15.2)
$30k to $39,999 | 1,789 (11.06) | 31 (5.5) | 90 (20.8)
$40k to $49,999 | 1,484 (9.17) | 21 (3.7) | 57 (13.2)
$50k to $59,999 | 1,404 (8.68) | 15 (2.7) | 50 (11.6)
$60k to $69,999 | 1,166 (7.21) | 9 (1.6) | 19 (4.4)
$70k and more | 4,582 (28.33) | 8 (1.4) | 54 (12.5)
Missing | 1,756 (10.85) | | 54
Country of Birth (n, % Canadian) | 5781 (81.4) | 1166 (67.4) | 387 (89.6)
Ever/current Alcohol Use (n, %) | 6550 (92.2) | 344 (22.8) | 411 (95.1)
Level of Physical Activity (n, %)
Low | 1,342 (19.0%) | 841 (48.6%) | 66 (15.3%)
Medium | 2,664 (37.7%) | 619 (35.8%) | 171 (39.6%)
High | 3,055 (43.3%) | 270 (15.6%) | 195 (45.1%)
Height [mean,( sd)]
Male | 174.6 (7.1, n=2998) | 170.5 (7.7, n=607) | 168.5 (7.4)
Female | 160.4 (6.4, n=4073) | 157.3 (7.4, n=993) | 155.4 (5.7)
All | 166.5 (9.7, n=7,001) | 162.3 (9.9, n=1,600) | 161.5 (9.2)
Weight [mean,( sd)]
Male | 82.8 (14.3, n=2990) | 72.6 (12.7, n=622) | 80.0 (12.9)
Female | 68.6 (13.8, n=4011) | 60.3 (12.5, n=1032) | 66.4 (12.8)
All | 74.6 (15.7, n=7,001) | 64.9 (13.9, n=1,554) | 72.7 (14.5)
Chronic conditions (n, %)
High Blood Pressure | 3,993 (56.2) | 614 (35.5) | 206 (47.7)^p^
Stroke | 283 (4.0) | 211 (12.2) | 0^p^
Diabetes | 1,258 (17.7) | 228 (13.2) | 40 (9.3)^p^
Myocardial Infarction | 876 (12.4) | 263 (15.2) | 57 (13.4)^p^

CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study of Health and Aging; IM = impossible match; IPAQ = International Physical Activity Questionnaire; k = thousand; n = sample size; NuAge = Quebec Longitudinal Study on Nutrition and Aging; sd = standard deviation

P Partial match.

The pre-statistical harmonization culminated in three data sets with combinable data on 13 variables of interest. Appendix B includes a complete summary of how the variables were operationalized in their respective studies and the final derived variable used in subsequent analyses.