# Methods and Results: Environmental Scans To Identify Methods of Combining Cognition Data and Statistical Harmonization Methods (Objective 1)

## Introduction

To address our first study objective, to identify approaches to statistical harmonization which could be used in the context of aggregate data and/or individual participant data meta-analysis of cognitive measures, we undertook two environmental scans in consultation with key informants and a Technical Expert Panel (TEP). By environmental scan we mean that the research question is not narrow, the search terms are quite broad, and single reviewers are involved in both consideration of eligibility of articles and in data extraction. In addition, the articles have not been reviewed for methodological quality in the usual sense of a systematic review, but methodological properties of the methods used are heavily scrutinized.

The purpose of our first scan was to identify what methods were currently being used to quantitatively combine cognition data in systematic reviews. Of particular interest was when the cognitive measures combined in the meta-analysis differed among studies to assess the current methods being employed by researchers to aggregate these nonuniform measures. In practice, we found that most studies either restricted their analyses to cognitive measures with a common scale or combined effect sizes across studies. None of the studies formally probed into whether the cognitive measures should be harmonized. To identify more sophisticated methods that would allow us to explore whether the cognitive data should be combined we undertook a second environmental scan to assess what types of statistical harmonization methods were used in the general literature. This scan was not restricted to the harmonization of cognitive measures; it was a general search of harmonization methods used in any context. Each environmental scan is described in detail below. The environmental scans culminated in the identification of statistical methods for harmonization that would be used to address study objectives two and three.

## Literature Scan—Studies Quantitatively Combining Data on Cognition

The first search was undertaken in a number of databases: Medline^®^, EMBASE^®^, Web of Science, and MathSciNet^®^ (January 2001 to September 2011). The search terms used for the first part of the search were “cognition” and “meta-analysis”. A similar search was undertaken using Google search engine. The search results were rapidly screened to identify articles of relevance to this review. The references of relevant articles were also checked and a search for more recent articles that cited the articles already identified as being of interest was undertaken.

### Inclusion and Exclusion Criteria

Any study that quantitatively combined individual-level or aggregate-level data on cognitive measures and was published in English was eligible. Cognitive measures were defined as one or more standardized neuropsychometric tests (i.e., measuring global function, executive function, psychomotor speed, attention, memory, or intelligence).

### Review Process

The scan of cognition meta-analyses resulted in 120 citations. A single rater reviewed the titles and abstracts of all articles to identify which articles contained a quantitative summary of cognitive data. The full-text was retrieved and reviewed for each article passing the title and abstract screening. Study level characteristics were extracted by one reviewer. These included a description of the populations, study design and number of studies included in the meta-analysis, the intervention of interest (if appropriate), the inclusion criteria, the types of cognitive measures and domains measured, and how the data were statistically combined.

### Results

The first level of the scan involved searching the subject heading “cognition” and then limiting the search to those studies that were meta-analyses. There were 121 potential meta-analyses of cognition measures identified. The abstract screen focused on identifying studies that reported a quantitative summary of cognitive data. There were 47 abstracts that passed this level of screening and the full text articles were retrieved. The full text screening involved reducing the number of studies to include only those that combined different cognitive measures, resulting in a total of 33 articles, which are summarized in Table 1.^36–68^ All meta-analyses used aggregate data. Most of the meta-analyses included observational studies (19, 57.6 percent); 14 (42.4 percent) were restricted to randomized controlled trials (RCTs). The populations ranged from school-aged children to adults aged 55 and older. The primary focus of the studies varied greatly, but most used the cognitive tests as an outcome associated with a putative harmful agent (e.g., mobile phone electromagnetic fields) or positive factor (e.g., being an expert athlete), or after an intervention (e.g., comparing off-pump vs. on-pump coronary artery revascularization). The cognitive measures differed over the meta-analyses. Most meta-analyses included multiple instruments that measured different aspects of cognition, (e.g., executive function, psychomotor speed).

Table 1 Summary articles describing meta-analyses of cognitive measures

Source Population Study Design # of Studies Included in Analysis | Intervention | Inclusion Criteria | Types of Cognitive Measures | Different Domains Looked at (i.e., Memory) | How Data Were Combined
Angevaren, M. 2008^37^ Individuals 55 years and older participating in RCTs assessing the effectiveness of physical activity on cognitive function RCTs 11 studies included | Physical activity programs | Studies were included if:; - they were published RCTs comparing aerobic physical activity programs with another intervention or no intervention; - participants were 55 years and older; [p.3] | - Simple RT; - Choice RT; - TMT part A and B; - Digit symbol substitution test; - Rand memory test story recall; - Ross Information Processing Assessment; - WAIS; - BVRT; - Digit span backward and forward; - 16 words delayed recall; - RAVLT delayed recall trial; - WMS; - Word comparison; - Task switching paradigm; - Verbal fluency; - Face recognition; - Stroop color word test; - Stopping task; - Digit vigilance; - Tracking; - Letter search; - Finger tapping; - Visual search; - Pursuit rotor task; [p. 23–24] | - Cognitive speed; - Verbal memory functions; - Visual memory functions; - Working memory; - Memory function; - Executive functions; - Perception; - Cognitive inhibition; - Visual attention; - Auditory attention; - Motor function; [p. 23–24] | - Neuropsychological tests included in the RCTs were organized into a number of categories measuring the same construct; - The weighted mean difference was used if studies applied the same cognitive tests and if the outcome measurements were on the same scale. In all other cases, the SMD was calculated; [p. 4]
Eilander, A. 2010^44^ Children ages 0–18 years participating in studies evaluating the impact of micronutrient supplementation on cognitive performance RCTs 19 studies included | Micronutrient supplementation | Studies were included if:; - they were randomized placebo-controlled trials evaluating the effect of micronutrient supplementation on cognitive performance; - they were trials focused on healthy children; - they reported cognitive results as primary or secondary outcome measures of the intervention; - they were trials where children were supplemented with ≥ 3 micronutrients with a placebo; [p. 116] | - BAS; - DG; - CPAS-R; - CTBS; - GMT; - MISIC; - NAR; - OOHMT; - PGI; - PMAT-FC; - NEPSY; - RAVLT; - SDMT; - WAIS; - WIAT; - WISC-III/R; [p. 123] | - Fluid intelligence; - Crystallized intelligence; - Short term memory; - Visual perception; - Retrieval ability; - Cognitive processing speed; - Sustained attention; - Motor skills; - Academic performance; [p. 116] | - If trials were using more than one cognitive measure to assess one cognitive domain, a standardized mean difference was calculated; - Effect sizes were calculated for individual trials by dividing the difference between the mean change in intervention and control group by the pooled SD; - Overall mean effect size was calculated by applying the random-effects model; [p.116–117]
Falkingham, M. 2010^45^ Anemic and nonanemic children and adults RCTs 14 studies included | Intervention groups received an oral iron supplement | Studies were included if:; - participants were human and at least 6 years old; - participants were randomized to an iron supplementation vs. a control; - the length of intervention was at least 4 weeks; - the additive effect of iron was clear; - and some objective measure of cognitive performance had to be evaluated; [p. 2] | - Raven’s Color Progressive Matrices; - Peabody Picture Vocabulary; - Rey Auditory Verbal Learning; - Wechsler’s Digit Span; - Mazes test; - Hopkins Verbal Learning Test; - Bourden-wisconsin concentration; [p.4] | - Attention and concentration; - IQ; - Memory; - Psychomotor; - Scholastic achievement; [p. 5] | - The inverse variance method was used for the meta-analysis; - Standardized mean differences were used in random effects meta-analysis; - Heterogeneity was measured using the I^2^ statistic; [p. 3]
Guilera, G. 2009^48^ Patients diagnosed with schizophrenia RCTs 18 studies included | Antipsychotic medications | Studies were included if:; - they were RCTs comparing atypical with typical antipsychotics in adults; - they focused on participants with a diagnosis of schizophrenia, schizo-affective or schizophreniform disorder; - they used a standardized neurological test listed in the Lezak manual; [p. 3–4] | - Stroop, CPT, TMT-A and B, CANTAB Rapid Visual Information Processing Test; - WCST, WISC-R, WAIS, HVOT; - WMS-R, CVLT, RCAVLT, HVLT; - NART, Peabody Picture Vocabulary Test; - Finger tapping, Grooved Pegboard test; - Benton Judgment of Lines; [p. 3] | - Attention and vigilance; - Automaticity and procedural learning; - General intellectual functioning; - Language and verbal comprehension; - Perceptual processing; - Psychomotricity; - Reasoning and problem solving; - Speed of processing; - Verbal learning and memory; - Visual learning and memory; - Working memory; [p. 3] | - Effect sizes were combined using a random effects model to create a weighted mean estimate for each of the cognitive domains and the global cognitive index; - Pooled effect sizes were weighted by applying the inverse variance method; [p. 5]
Hogervorst, E. 2010^49^ Postmenopausal women RCTs 38 studies included | Hormone replacement therapy | Studies were included if:; - they were RCTs assessing hormone replacement therapy and its effect on cognitive function in postmenopausal women; - they used a placebo treated control group; - they included cognitive measures; [p. 65] | - paragraph recall, story recall; - COWAT, FAS; - Face recognition, BVRT, RAVLT; - SRT, Digit Span; - Stroop, TMT-B; - MMSE; [p. 66] | - Verbal memory; - Verbal fluency; - Visual memory; - Concentration; - Executive function; - Visuospatial; [p. 66] | - A table driven meta-analytical approach was used to address the difficulty in comparing individual tests; - Analyses were conducted using general linear models with post hoc Tukey tests or M-W U-tests and Chi-Square for categorical data; - Associations between continuous data were assessed by conducting Spearman’s rank correlations; [p. 65–66]
Hogervorst, E. 2009^50^ Postmenopausal women that have been diagnosed with Alzheimer’s disease or other dementia syndromes RCTs 7 studies included | Interventions included administering estrogens alone or combined with a progestogen | Studies were included if:; - they were double-blind RCTs focusing on the effect of ERT and HRT on cognitive function; - the treatment period was at least 2 weeks; - participants were postmenopausal women with Alzheimer’s disease or other types of dementia; [p. 1] | - MMSE, BIMC, ADAS-Cog, HSD; - WMS, BSRT, CERAD, Digit span; - VRT, visual span, face recognition, ROVMT; - Boston naming test, Token test; - TMT-A and B, DSST, Stroop, Digit Span backward; [p. 2] | - General cognitive function; - Verbal memory; - Visual memory; - Language; - Speed and efficiency of information processing; [p. 4] | - Weighted mean difference was used in the meta-analysis when studies used the same treatment and test outcome measure. A fixed effect model was used if there was no significant heterogeneity; - Standardized mean difference was used with either fixed effect or random effects models in studies where they used different types of treatment or different tests to measure the same construct; [p. 6]
Li, H. 2011^51^ Individuals with mild cognitive impairment RCTs 17 studies included in meta-analysis [p.287] | Cognitive training for people with mild cognitive impairment | - Study should focus intervention on MCI group and include pre- and post-test data of the intervention group; - Must include cognitive stimulation/training or cognitive rehabilitation method; - Study must provide means, standard deviations, t test or F test and sample size of intervention group; - Study should have at least 1 dependent variable of cognitive test or functional ability assessment; [p.286] | - Episodic and semantic memory tests; - Trail Making Test (Part A and Part B); - WCST; - Figure rey-copy, pattern and picture reproduction, facial recognition test; - MMSE; [p. 286–287] | - Memory; - Executive functioning; - Attention/processing speed; - Visuospatial ability; - Changes of the Mini Mental State Examination (MMSE) during the intervention; - Emotional state—focusing on depression and anxiety; [p. 286–287] | - Effect sizes (Cohen’s d) for the differences in post- and pre-test, followup test and pre-test performances of the intervention were calculated (differences between the means of pre-test and post-test, divided by the pooled standard deviation); - When the studies included several tests of a certain domain, each domain of tests was averaged to one pooled effect size.; [p.287]
Karsdorp, PA. 2007^53^ Children and adolescents with congenital heart disease (CHD) RCTs 11 studies included | No intervention | Studies were included if:; - they were published in a peer-reviewed English or German journal; - they only used patients with CHD; - participants were between 2 and 19 years old (mean age ≥4); - participants had all had surgery or interventional catheterization; - they used the CBCL (parent form) and/or measures of cognitive function; - they provided data required to calculate effect sizes; - they used a control group; [p. 529] | - BAS; - BSID; - DAS; - HAWIE; - HAWIK; - HAWIVA; - KABC; - LIS; - MSCA; - SB; - WISC; - WPPSI; [p.533] | - Specific domains not reported | - Meta-analytic procedures focused on effect sizes modeled after the techniques of Hunter and Schmidt; - Standardized mean difference was used as the estimate of effect size; - Weight mean effect size was calculated to account for differences in sample size; [p. 529]
Lethaby, A. 2008^55^ Healthy women who had undergone natural or surgical menopause RCTs 16 studies included | Hormone replacement therapy | Studies were included if:; - they were double-blind RCTs assessing the effect of estrogen replacement therapy or hormone replacement therapy on cognitive function; - the treatment period was at least 2 weeks; - participants were postmenopausal women; [p. 1] | - CAMCOG, Folstein Mini-Mental State Examination, MMSE; - WMS, CVLT, Boston naming test; - VRT, BVRT, VMT; - TMT-A, DSST, Finger tapping, Grooved Pegboard test, Stroop; - Letter cancellation tests; - WCST, WAIS, COWAT, Digits backward; [p. 5] | - Global cognitive function; - Verbal memory and language; - Visuospatial; - Speed tests, Attention and Manual Dexterity Semantic Memory; - Mental rotation tests and accuracy; - Executive function; [p. 5] | - Using the fixed effects model, the weighted mean difference was calculated for continuous data; - Odds ratios were calculated for dichotomous data through the use of a fixed effects model; - WMD was used as the outcome measure in trials that were measuring the same outcomes; - When trials were not comparable (i.e., different tests within the same cognitive domain, different kinds of participants or different interventions) the standardized mean was calculated using a random effects model; [p. 7]
Marasco, SF. 2008^56^ Patients with coronary artery bypass grafting RCTs 8 studies included | Off-pump (beating heart) coronary artery bypass grafting vs. on-pump | Studies were included if:; - they were prospective randomized control trials comparing off-pump vs. on-pump coronary artery revascularization; - neurocognitive testing was conducted; [p. 962] | - Rey Auditory Verbal Learning; - Grooved Pegboard; - TMT—Part A and B; - WAIS III; - Digit Symbol substitution test; [p. 963] | - Verbal memory; - Motor capacity; - Divided attention and executive function; - Information processing; [p. 963] | - Outcomes were analyzed as continuous variables; - Weighted mean difference was calculated for each outcome; - A fixed effect or random effects model was selected based on the degree of heterogeneity; [p. 962]
Martin, M. 2011^36^ Healthy older people (age 60 yrs and older) and people with mild cognitive impairment RCTs 36 studies included | Mental training, problem solving training, speed training, cognitive restructuration technique | Studies were included if:; - they described cognitive training specific domains of cognitive function such as memory, attention, or speed; - they were published, written in English or German, and presented in a journal article; - they were an RCT; - they had a minimum of 2 measurements and assessment; [p. 4] | - problem solving; - verbal episodic memory; - Luria; - TMT; - visuomanual coordination; - short term memory; - immediate recall; - recent logic execution memory; - abstraction proverbs; - phonematic fluency; - IADL; - Guild Memory Test; - supermarket test; - subjective memory tests; - Geriatric Depression Scale; - alpha span (working memory) total score; - Brown-Peterson: secondary memory, primary memory; - free recall of digit spans; - UFOV; - Road Sign Test; - letter comparison; - global auditory memory score; - letter series test; - word series test; - letter sets test; - Hopkins Verbal Learning Test; - Rivermead Behavioural Memory Test; - Hopkins Prospective Memory Task questionnaires: Memory Controllability Inventory, Memory Functioning Questionnaire; - short story recall; - letter and semantic verbal fluency; - Raven matrices; - Rey figure; - immediate and delayed recall of words; - shopping list; - name-faces; - Benton visual retention test; - total word recall; - long-term retrieval; - vocabulary subtest of Wechsler Adult Intelligence Scale-Revised; - face-name recall; - NEO-PI; - Physical and cognitive variables Wechsler Memory Scale | - Memory; - Attention; - Speed; [p. 4] | - When rating scales used in the trials had a number of categories > 10 the data were treated as continuous outcomes arising from a normal distribution; - For binary outcomes the odds ratio was used to measure treatment effect; - A weighted estimate of the typical treatment effect across trials was calculated; [p. 7]
Metternich, B. 2010^57^ Patients reporting subjective memory complaints (SMC) RCTs 14 studies included | Nonpharmacological interventions (i.e., Mental Training, Psycho-educational programs, physical training) | Studies were included if:; - they focused on nondrug interventions; - they were published in peer-reviewed journals in English, Dutch, German or French; - they were RCTs; - if they reported sufficient data to conduct the meta-analyses; [p. 8] | - MIA, MCI, MFQ; - Face-Name Task; - CVLT, HVLT, Visual Verbal Learning Test, WMS, Buschke Selective Reminding Test, Guild Memory Test; [p. 8] | - Subjective memory; - Objective memory; [p. 8] | - Standardized mean differences of change scores were calculated for all comparisons; - Due to the small sample size of some of the trials, Hedges’ adjusted g was used; - To account for clinical and methodological diversity, a random effects model was used to summarize individual effect sizes; [p. 9]
Repantis, D. 2010^62^ Participants enrolled in studies looking at using modafinil and MPH for neuro-enhancement RCTs 91 studies included | Modafinil and MPH use | Studies were included if:; - they were published single- or double-blind RCTs comparing MPH or modafinil with a placebo; - participants showed no signs of psychiatric disorder, cognitive decline or other diseases; [p. 188] | Not reported | - Attention and vigilance; - Memory and learning; - Executive functions and information processing; [p. 201–202] | - A standardized effect difference was calculated for the appropriate test parameters of each study; - A linear mixed model was applied in the analysis, to account for heterogeneity and correlation within studies; - A meta-analysis and meta-regression were conducted based on the linear mixed model; [p. 189]
Woodward, ND. 2007^67^ Prospective, double-blind randomized trials 16 studies included | Atypical antipsychotic drugs | - Studies were included if:; - they involved participants diagnosed with schizophrenia or schizoaffective disorder; - they used a prospective study design with a baseline assessment and a minimum of one followup; - the trial lasted at least 1 week; - no antipsychotic meds were administered with the exception of the study meds; - there was a minimum baseline sample size of 10; - the study was published in a peer-reviewed journal as of April 2004; - findings of neuropsychological change to treatment were reported for at least one of the identified tests; [p. 213] | - TMT-A and B; - Continuous performance test; - Digit symbol substitution/modalities test; - WCST; - CVLT, RVLT, BVLT; - Controlled Oral Word Association Test, Category Instance Generation Test; - Finger Tapping/Oscillation Test; - Grooved Pegboard Test; [p. 214] | - Attention; - Processing speed; - Executive function; - Verbal learning; - Delayed verbal recall; - Verbal fluency; - Motor skill; [p. 214] | - Effect sizes were calculated for overall cognitive function by calculating a Global Cognitive Index; - In cases where studies failed to report a standardized cognitive summary score, the Global Cognitive Index was determined by averaging effect sizes across all neuropsychological tests used in the study; - A weighted average effect size was calculated for the Global Cognitive Index and specific neuropsychological tests by combining effect sizes across studies following the fixed effects model; [p. 214–215]
Campbell, LK. 2007^43^ Children that have received treatment for Acute Lymphocytic Leukemia (ALL) Observational 28 studies included | Treatment vs. healthy comparison group | Studies were included if:; - they were published in English; - they included original data on post-treatment neurocognitive functioning of childhood ALL patients; - they included valid and reliable neurocognitive measures; - they included published normative data; [p. 65] | - WPPSI, WISC, WAIS, Standford-Binet, MSCA, K-BIT, KABC; - WRAT, Woodcock-Johnson Tests of Achievement; - Digit span, TMT, Stroop; - WISC; - Finger tapping, Grooved Pegboard, Purdue Pegboard; - WRAML, CVLT, RAVLT, Buschke Selective Reminding Task; - VMI, Rey, Weschler Block design, Judgment of Line Orientation; - Benton Visual Retention; [p. 66] | - Overall cognitive functioning; - Academic achievement; - Attention; - Executive functioning; - Information processing speed; - Psychomotor skill; - Verbal memory; - Visuospatial skill; - Visuospatial memory; [p. 66] | - A random effects model was applied to calculate Hedges’ g for each study outcome; - Effect sizes were averaged to calculate a single effect size for the analysis if multiple measures were applied to evaluate the same neurocognitive domain in a study; [p.66]
Goodman, M. 2002^46^ Workers that have been exposed to lead and who have not been exposed Observational 22 studies included | Exposed to lead in the workplace | Studies were included if:; - there was a central tendency for blood concentration <70 μg/dl; - totals of exposed and unexposed participants were reported; - test score means and measures of dispersion were provided for both exposed and unexposed participants; [p. 218] | - block design test; - logical memory test; - digit symbol substitution test; - visual interference; - similarities; - Bento n visual retention; - Paired associates; - Visual reproduction; - Flicker fusion; - Arithmetic; - Symbol digit learning; - Digit span (forward and backward); - TMT—A and B; - Simple reaction time; - Picture completion; - Grooved Pegboard; - Tapping rate; [p. 221] | - Specific domains not reported | - Fixed and random effects models were both used for each analyses due to the variation in testing procedures, scoring practices, variations in study samples, and assumptions of homogeneity; [p. 219]
Grant, I. 2003^47^ Cannabis-using and nondrug using participants in studies looking at neurocognitive effects of cannabis use Observational 11 studies included | Cannabis use vs. no cannabis use | Studies were included if:; - they included a group of “cannabis only” users; - they included a control group; - they included appropriate information for calculating effect size; - neuropsychological tests were included in outcome measures; - cannabis group was drug-free on day of testing; - they included information regarding other substance use in cannabis group; - they included history of neurological or psychiatric problems; - they included data on length of abstinence from cannabis before testing; [p. 681] | - WAIS-R Digit Span and Digit Vigilance; - WAIS-R Vocabulary, Verbal Fluency; - WCST, RAVENS; - WAIS-R Block Design, Object Assembly; - Grooved Pegboard, Finger Tapping; - CVLT, RAVLT; [p. 683] | - Simple reaction time; - Attention; - Verbal/language; - Abstraction/executive functioning; - Perceptual motor; - Simple motor; - Learning; - Forgetting/retrieval; [p. 683] | - The method prescribed by Hedges and Olkin was applied based on the assumption that different tests measuring the same cognitive domain would likely be correlated; - A fixed effects model was used due to the likelihood of heterogeneity in data across studies; - An overall neurocognitive effect size was calculated by pooling effect sizes across domains; [p. 683]
Valentini, E. 2010^64^ Participants of studies assessing the psychomotor effects of mobile phone electromagnetic fields (EMF) Observational 24 studies included | Exposure to EMF | Studies were included if:; - they were in English and reported human provocation/laboratory studies on the effect of modulated RF-EMF on behavioral outcomes; - they had an experimental design using real and sham exposure to EMF; - the data concentrated on acute effects of GSM/UMTS-like exposures; - they reported speed measures; they used comparable tasks or used them more than once | - Trail Making Test—version B; - Two-choice reaction time, ten-choice reaction time; - Simple reaction time task; - Subtraction; - Sentence verification; - Vigilance task; [p. 711] | - Attention and speed of processing; - Divided and sustained attention; - Working memory; - Semantic memory; [p. 709] | - Statistical values were extracted to calculate the standardized mean difference; - Pooled effect size was calculated by weighing each effect size by its corresponding sample size (Hedges and Olkin); [p. 711]
Wheaton, P. 2009^66^ Adults with Traumatic Brain Injury (TBI) Independent groups repeated measures design and independent groups design 22 studies included | Drug treatment for TBI | Studies were included if they:; - were published in a journal in English; - included a TBI control group matched to the treatment group based on age and severity of injury; - were not a case study;; - had TBI treatment and control groups that had suffered nonpenetrating TBIs; - both groups were given measures of cognition and/or behaviour to assess outcome; - treatment group was given drug treatment in the early stages following the injury; - no subject had sustained a TBI prior to the current injury, no pre-existing impairments, no history of mental health problems or substance abuse; - participants not recently treated with pharmaceuticals to improve behaviour or enhance cognition; - results reported in a manner that allowed for calculation of effect size; - subjects were 16 years or older; [p. 469] | - PASAT; - Story memory; [p. 473] | - Attention; - Memory; - General cognition; [p. 474] | - Cohen’s d was used to calculate effect size; - Effect size was calculated for each score for all outcome measures of cognition and behaviour. If there were multiple scores for a particular outcome measure then they were combined and a mean effect size was calculated for that measure; - Effect sizes from different studies using the same measure were averaged to permit evaluation of the combined findings; [p. 470]
Barth, A. 2008^39^ Subjects enrolled in studies investigating the effects of electromagnetic fields emitted by GSM mobile phones Single or double-blind experimental study design [p.343] 10 studies were included in the meta-analysis [p. 342] | No intervention | - Treatment group and control group with baseline measures or repeated measurements of subjects with mobile phone switched on and switched off; - Mean and SD of the dependent variables documented for both groups or both times or test statistics; - Single-blind or double-blind experimental study design; - Exposure by a GSM mobile phone specified at a range of 900 MHz to 1800 MHz under two conditions: on vs. off; - Enrolled participants were considered healthy; - Study must include at least one neuropsychological test that is used in another study; [p. 343] | - SRT; - CRT; - VIG; - SUB; - VER; - N-Back test; - TMT; - Digit span forward and backward; - Spatial span forward and backward; [p.343] | - Information processing; - Reaction time; - Attention; - Memory; - Executive functions; [p. 343] | - Results of all studies were first transformed into their respective effect sizes, indicating whether there was an effect of mobile phones—these effect sizes were transformed into the meta-analytic delta-measure; - An assumption was made that there was a common population effect in the different studies and that a single effect size could be calculated for each individual study; - When homogeneity for single effect sizes was not provided, a random effects model was applied; [p. 344]
Brands, A. 2005^42^ Patients with Type 1 diabetes Cross-sectional design 33 studies | No intervention | Studies were included if:; - they were published in English after 1980 and before 2004,; - they focused solely on adults 18 years and older with type 1 diabetes,; - had a defined control group,; - measured cognitive performance using standard neuropsychological or reliable experimental testing methods at normal glucose values,; - original studies and test scores were provided for the experimental and control groups or if statistics such as the exact t or F values were provided; [p. 726] | - Measures not reported | - Overall intelligence; - Working memory; - Learning immediate memory; - Delayed memory; - Psychomotor efficiency; - Speed of information process; - Motor speed; - Attention; - Cognitive flexibility; - Visual perception; - Language; [p. 731] | - Effect sizes were calculated for every result; - A combined d value was included in the meta-analysis.; - The statistic Q was calculated to determine the heterogeneity of the sample; - Tests measuring the same cognitive domain were taken together in the analysis. All cognitive domains were pooled into an overall d value and then separate meta-analyses were conducted for the different cognitive domains; [p. 727]
Sibley, B. 2003^63^ Elementary school-aged children Quasi-experimental and cross-sectional 44 studies included in meta-analysis [p.245] | No intervention | - Studies exploring the relationship between physical activity and cognition or academic performance were included; - English studies conducted before January 2002 were included; [p. 245] | - Measures not reported | - Perceptual skills; - IQ; - Achievement; - Verbal tests; - Math tests; - Memory; - Developmental level/academic readiness; [p. 247] | - Effect sizes were calculated for each study and then an overall ES was calculated; - Each level of the moderator variables had an effect size calculated; - Homogeneity tests were done by partitioning the total variance into between groups variance and within groups variance; [p. 245–247]
Balint, S. 2009^38^ Adult ADHD patients and control group participants in studies looking at differences in neuropsychological performance in ADHD vs. normal control subjects Observational 25 studies included | No intervention | Studies were included if:; - they included at least one measure of attention; - they compared performance of ADHD subjects with a normal control group; - participants were adults (>18 years); - raw data for effect size calculation included in the paper; - ADHD diagnosis obtained using DSM-III-R or DSM-IV criteria; - articles were published in English; [p. 1338] | - Stroop; - TMT; - WAIS-R Digit Span and Digit Symbol subtests; - CPT; [p. 1338–1340] | - Attention (simple, focused and sustained); [p. 1338–1340] | - Pooled effect size was calculated across the studies to determine the differences between the ADHD group and control group; - A random effects meta-regression was used to calculate the pooled effect size of the difference between the ADHD vs. the control group; [p. 1340]
Bhutta, A. 2002^40^ School-aged children who were born preterm Case-control studies 15 studies were included in the meta-analysis [p.729] | No intervention | - Studies had to have a case-control design; - Had to report cognitive data, behavioral data or both; - Had to perform evaluations after the fifth birthday of participants; - Had to have an attrition rate of less than 30%; - Had to be published in 1980 or later; [p.729] | - BAS; - MIQS; - WPPSI; - KABC; - WISC; [p. 731] | - IQ; - Other domains not reported | - For each study, the nonstandardized difference between mean cognitive test score of cases and controls was weighted by the inverse of the variance for this difference; - The weighted mean differences were then pooled across studies to compute an overall mean cognitive difference between cases and controls; - Random-effects and fixed-effects least-square regression models were used for combining the results in the meta-analysis; [p.729]
Bora, E. 2009^41^ Participants in studies assessing neuropsychological deficits in euthymic patients Observational 62 studies included | No intervention | - Studies were included if:; - they included neuropsychological data on remitted adults with bipolar disorder or first-degree relatives of patients with bipolar disorder; - they used a healthy control group; - they included mean test scores and standard deviations; - they used at least one cognitive measure that was used in at least three studies in both bipolar patients and healthy relatives of bipolar patients; [p. 3] | - RAVLT, CVLT, VLT; - WMS-R; - CPT; - TMT-A and B; - FAS; - WCST, CANTAB; - WAIS-R Digit Span; - Stroop; - ROCF; - NART; [p. 8] | - Verbal learning and memory; - Visual memory; - Sustained attention; - Processing speed; - Verbal fluency; - Set shifting; - Working memory; - Response inhibition; - Visuospatial abilities; - General intelligence; [p. 8] | - The standardized mean difference method was used; - A random effects model was used as there was heterogeneity for many of the analyses; - Meta-regression analyses were conducted with the random effects model using restricted-information maximum likelihood method with a significance level of p<0.05; [p. 12]
Jansen, C. 2005^52^ Cancer patients who had or were currently receiving chemotherapy Observational 16 studies included | No intervention | Studies were included if:; - they used original study data; - they used an adult sample; - they conducted neuropsychological testing of cancer patients who had or were presently receiving chemotherapy; - they used reliable, valid, and standardized neuropsychologic tests; - they reported sufficient information on at least one domain of cognitive function to estimate effect size; [p.2223] | - CPT; - DRS; - HRNB; - HSCS; - RBANS; - RCFT; - TMT; - WAIS; - WMS; [p. 2227] | - Attention or concentration; - Executive function; - Speed of information processing; - Language; - Motor function; - Visuospatial skill; - Verbal memory; - Visual memory; [p. 2224] | - Potential for bias was corrected by weighting the standardized mean difference effect size for each test by the sample size and pooled variance; - For studies using more than one test to measure a specific cognitive domain, an average effect size was calculated for that domain; - Test producing numerous scores had an average effect size calculated for that test; [p. 2224]
Krabbendam, L. 2005^54^ Patients with bipolar disorder or schizophrenia Observational 31 studies were included | No intervention | Studies were included if they:; - evaluated cognitive performance using standardized neuropsychological testing procedures; - compared adult participants with schizophrenia and with bipolar disorder; - provided test results of both participant groups, or exact p-values, t-values, or F-values; - were published in a peer-reviewed English language journal; [p.138] | - Digit Span, Letter-Number Span; - DSST, Trailmaking Test Part A; - Trailmaking Test Part B, Stroop Color-Word interference; - Wisconsin Card Sorting Test; [p.139] | - Verbal working memory; - Verbal fluency; - Mental speed; - Executive control; - Concept formation and shifting; [p. 139] | - An effect size was determined for each test parameter; - In situations where means and SD were not provided, d-values were calculated from exact p-values, t-values, or F-values; - In instances where multiple tests were reported for one cognitive domain, they were combined into one d-value; - Homogeneity was also tested using the Q-statistic; [p. 139]
McDermott, LM. 2009^58^ Patients diagnosed with depression Observational 14 studies included | No intervention | Studies were included if:; - they included a sample of participants diagnosed with major or minor depression; - they reported means and standard deviations of neuropsychological test scores; - they assessed the impact of severity of depression on performance on neuropsychological tests; [p. 2] | - WCST, word fluency, TMT-B, COWAT, Hayling test B, Stroop, MCST, digit span (forwards and backward), CANTAB; - Semantic fluency test, Verbal fluency test, TMT-A, MFFT-20, ZVT, TAP, digit symbol substitution test, processing speed, Grooved Pegboard; - RAVLT, AVLT, signal recognition, recognition test; [p. 3] | - Episodic memory; - Executive function; - Processing speed; - Semantic memory; - Visuospatial memory; [p. 3] | - The population effect size was calculated using the study effect sizes and sample sizes; - A separate meta-analysis was conducted to replicate results for each cognitive domain and two sets of timed and untimed tests; [p. 3]
Naguib, JM. 2009^59^ Children with type 1 diabetes Case-control design 24 studies included | No intervention | Studies were included if:; - the sample was people ≤19 years old with type 1 diabetes; - they used a case-control design; - used standardized neuropsychological tests of seven cognitive domains; [p. 271] | Not reported | - Intelligence; - Visuospatial; - Language and education; - Memory and learning; - Psychomotor activity; - Attention; - Executive function; [p. 274] | - Cohen’s d statistic was calculated for every test of a particular study; - In each cognitive subdomain a meta-analysis was conducted when a minimum of three studies had evaluated the same subdomain; - A fixed effects model of meta-analysis was applied; [p. 275]
Nieto, RG. 2011^60^ Patients with early onset schizophrenia or pediatric bipolar disorder Observational 12 studies included | No intervention | Studies were included if:; - they published in English; - they included a healthy comparison group; - data were available to calculate effect sizes; [p. 267] | Not reported | - Attention; - Working memory; - Executive control; - Visual memory; - Verbal learning and memory; - Visuospatial skills; - Verbal fluency; - Processing speed; - Motor skills; [p. 268] | - Standardized mean differences were calculated using Hedges and Olkin’s method (difference between the means of each of the diagnosed groups and control group divided by the pooled standard deviation); - A random effects model was used for the meta-analysis; [p. 268]
Quinn, TJ. 2011^61^ Adult patients participating in studies studying the association between circulating hemostatic measures and cognitive impairment Cross-sectional, cohort and case control, and longitudinal studies were included 21 studies included | No intervention | Studies were included if:; - the sample included only adults (18 years or older); - they were original research; - the analysis included measures of at least one circulating blood biomarker; - the biomarker was pertinent to hemostasis; - the analysis included at least one measure of cognitive function, cognitive impairment or dementia; - the data included was case-control, cross-sectional, longitudinal or a combination; [p. 1476] | - DST; - LM; - RAVENS; - VFT; [p. 1478] | - Speed of processing; - Verbal declarative memory; - Nonverbal reasoning; - Executive function; - General composite cognitive function; [p. 1478] | - Fixed effect and random effects models were both used. Random effects models were favored when there was substantial heterogeneity and three or more studies; [p. 1478]
Voss, MW. 2010^65^ Participants in studies exploring the relationship between sport expertise and cognition Observational 20 studies included | No intervention | Studies were included if:; - they were published in English; - used a controlled laboratory examination of cognitive skills; - they compared expert athletes with a matched control group of nonexpert athletes; [p. 815] | - Not reported | - Attentional cuing; - Processing speed; [p. 814] | - Effect sizes for each study were calculated using Hedges’ formula; - A random effects model was used to determine the effect of sport expertise on cognition. An average of the effect sizes for multiple cognitive measures was calculated to determine the mean effect size estimate per study; [p. 818]
Zhang, JP. 2010^68^ Healthy participants in studies focusing on genetic variation in DTNBP1 and general cognitive ability Observational 8 studies included | No intervention | Studies were included if:; - they reported the relationship between DTNBP1 polymorphisms and cognition in humans; - they involved healthy control participants; - they included the full-scale IQ score; [p. 1127] | - CANTAB; - COWAT; - CPT-I/P; - CVLT; - MWT-B; - WAIS-III; - WAIS-R; - WMS-III; - WRAT-3; [p. 1128] | - General cognitive ability | - Hedges’ g was applied as the effect size measure; - Raw IQ scores were used to calculate effect sizes in each study as different studies used different covariates; - Pooled effect sizes across studies were calculated using a random effects model; - Q and I^2^ statistics were used to assess heterogeneity; [p. 1129]

ADAS-Cog = Alzheimer’s Disease Assessment Scale-Cognitive; ADHD = attention deficit/hyperactivity disorder; ALL = acute lymphocytic leukemia; AVLT = Auditory Verbal Learning Test; BAS = British Ability Scale; BIMC = Blessed Information-Memory-Concentration; BSID = Bayley Scales of Infant Development; BSRT = Buschke Selective Reminding Test; BVLT = Buschke Verbal Learning Test; BVRT = Benton Visual Retention Test; CAMCOG = Cambridge Cognition Examination; CANTAB = Cambridge Neuropsychological Test Automated Battery; CBCL = Child Behaviour Checklist; CERAD = Consortium to Establish a Registry for Alzheimer’s Disease; CHD = congenital heart disease; Choice RT = Choice Reaction Time; COWAT = Controlled Oral Word Association Test; CPAS-R = Cognitive Psychomotor Assessment System-Revised; CPT = Continuous Performance Test; CPT-I/P = Continuous Performance Test-Identical Pairs Version; CRT = Choice Reaction Task; CTBS = Comprehensive Test of Basic Skills; CVLT = California Verbal Learning Test; DAS = Differential Ability Scale; DG = Differentiele Geschiktheidsbatterij; DRS = Dementia Rating Scale; DSM (-III-R, -IV) = Diagnostic and Statistical Manual of Mental Disorders (3^rd^ Edition-Revised, 4^th^ Edition); DSST = Digit symbol substitution test; DTNBP1 =; EMF = electromagnetic fields; ERT = Estrogen replacement therapy; ES = effect size; FAS = FAS, letter fluency test; GCI = Global Cognitive Index; GSM/UMTS = Global System for Mobile Communications (originally Groupe Spécial Mobile)/Universal Mobile Telecommunications System; GMT = Group Mathematics Test; GSM = Global System for Mobile Communications (originally Groupe Spécial Mobile); HAWIE = Hamburger Wechsler Intelligence Test for Adults; HAWIK = Hamburger Wechsler Intelligence Test for Children; HAWIVA = Hamburger Wechsler for Children in Pre-school Age; HRNB = Halstein-Reitan Neuropsychologic Battery; HRT = hormone replacement therapy; HSCS = High Sensitivity Cognitive Screen; HSD = Hasegawa dementia scale; HVLT = Hopkins Verbal Learning Test; HVOT = Hooper Visual Organization Test; IQ = intelligence quotient; KABC = Kaufman Assessment Battery of Childhood; K-BIT = Kaufman Brief Intelligence Test; LIS = Leiter International Scale; LM = logical memory; MCI = Memory Controllability Inventory; MCST = Modified Card Sorting Test; MFFT-20 = Matching Familiar Figures Test-20; MFQ = Memory Functioning Questionnaire; MHz = megahertz; MIA = Metamemory in Adulthood Questionnaire; MIQS = McCarthy IQ Scale; MISIC = Malin’s Intelligence Scale for Children; MMSE = Mini Mental State Examination; MPH = methylphenidate; MSCA = McCarthy Scales of Children’s Abilities; MWT-B = Mehrfachwahl-Wortschatz-Intelligenztest-Version B; NAR = Neale Analysis of Reading; NART = National Adult Reading Test; NEPSY = Developmental Neuropsychological Assessment; OOHMT = Otis Ottawa d’Habitele Mentale Test; PASAT = Paced Auditory Serial Addition Test; PGI = Post Graduate Institute (India); PMAT-FC = Primary Mental Abilities Test for Filipino Children; RAVENS = Raven’s progressive matrices; RAVLT = Rey Auditory Verbal Learning Test; RBANS = Repeatable Battery for the Assessment of Neuropsychologic Status; RCAVLT = Rey and Crawford Auditory Verbal Learning Test; RCFT = Rey-Osterrieth Complex Figure Test; RCT = randomized controlled trial; RIPA = Ross Information Processing Assessment; ROCF = Rey Osterreich Complex Figure; ROVMT = Rey-Osterrieth Visual Memory Test; RVLT = Rey Visual Learning Test; SB = Stanford Binet Scale; SD = standard deviation; SDMT = Symbol Digit Modalities Test; Simple RT = Simple reaction time; SMC = subjective memory complaints; SMD = standardized mean difference; SRT = Simple Reaction Task; SUB = Subtraction; TAP = Test of Attentional Performance; TBI = traumatic brain injury; TMT = Trail Making Test; VER = Sentence Verification; VFT = verbal fluency test; VIG = Vigilance; VLT = verbal learning test; VMI = visual-motor integration; VMT = Visuospatial Memory Test; VRT = Visual Retention Test; vs. = versus; WAIS = Wechsler Adult Intelligence Scale; WAIS-R = Wechsler Adult Intelligence Scale-Revised; WCST = Wisconsin Card Sorting Test; WIAT = Wechsler Individual Achievement Test Screener; WISC (-III, -R) = Wechsler Intelligence Scale for Children (3^rd^ Edition, Revised); WMD = weighted mean difference; WMS = Wechsler Memory Scale; WMS-III = Wechsler Memory Scale-Third Edition; WMS-III = Wechsler Memory Scale-Third Edition; WMS-R = Wechsler Memory Scale-Third Edition-Revised; WPPSI = Wechsler Preschool and Primary Scale of Intelligence; WRAML = Wide Range Assessment of Memory and Learning; WRAT = Wide Range Achievement Test; WRAT-3 = Wide Range Achievement Test-Third Edition; ZVT = Zahlen-Verbindungs-Test

All meta-analyses including cognition outcomes either restricted their analyses to a subset of studies for which cognitive measures with a common scale were used or effect sizes were combined across studies. In all cases, the cognitive measures were continuous variables. The most common method of analysis was to combine standardized mean differences or effect sizes across studies. When the measures of cognition were consistent across studies or were comparable tests with a normalized scale, a weighted mean difference was used. Four studies38,40,41,62 used meta-regression; three of the four used a standardized effect size, Cohen’s d, as the dependent variable;38,41,62 and one used a weighted mean difference of normalized comparable tests40

## Literature Scan—Statistical Methods for Data Harmonization

Identifying literature on statistical methods of data harmonization is challenging as there are no standard keywords or mesh terms used to identify this literature in the bibliographic databases. The initial set of keywords and searching terms were reviewed by the key informants and the TEP to identify additional potential search terms. A focused search was undertaken in a number of databases: Medline^®^, EMBASE^®^, Web of Science, and MathSciNet^®^(January 2001 to September 2011). The final set of search terms used were “individual patient data,” OR IPD, OR pooling, OR “multiple imputation,” OR “data harmonization,” OR “meta-analysis methods.” A similar search was undertaken using Google search engine. The search results were rapidly screened to identify articles of relevance to this review. The references of relevant articles were checked and a search for more recent articles that cited the articles already identified as being of interest was undertaken. These references were further supplemented by articles identified by key informants and the TEP increase the comprehensiveness of the search.

### Inclusion and Exclusion Criteria

Any study that reported statistical methods for retrospective harmonization of survey data was included. For the purpose of this review, harmonization was defined as “procedures aimed at achieving and improving the comparability of different surveys”.69 We adapted this definition to include study designs other than surveys. For completeness, these studies were supplemented with articles on the conduct and methodology of individual participant data (IPD) meta-analysis, methods for evaluating equivalence (i.e., whether instruments measure the same construct or latent variable, latent trait, or factor across groups or over time), imputation methods, and examples of data harmonization.

### Review Process

Because the numbers were relatively small (63 articles), all identified statistical harmonization methodology articles underwent full text screening for relevance by at least two raters. Data extracted from the methodology articles included a description of the statistical method used, the context in which it was used, and the pros and cons of the method.

### Results

The scan of statistical methods used for harmonization resulted in 63 unique articles. Of the 63 articles, 53^2,8,69–119^ (84.1 percent) met the inclusion criteria. The 10 excluded articles that were not directly relevant to this review are listed in Appendix A. Seven of the 53 articles (13.2 percent) described methods for statistical harmonization (Table 2). Ten articles (18.9 percent) focused on the conduct of IPD meta-analysis and an additional 6 articles (11.3 percent) focused on IPD meta-analysis methodology. Six articles (11.3 percent) reviewed imputation methods and the appropriateness of their use and 2 articles (3.8 percent) described methods for evaluating equivalence of item functioning across study subgroups. A summary of these supplemental studies are in Table 3. Finally, 22 articles (40.7 percent) reported the results of 16 unique statistical harmonization analyses undertaken in different contexts (Table 4).

Table 2 Summary articles describing statistical methods for data harmonization

Study | Method | Context | Description | Pro | Con
Bauer, DJ. 2009^70^ | Linear factor analysis (LFA) | This article compares different psychometric methods for developing commensurate measures in the context of integrative data analysis (the simultaneous analysis of data obtained from two or more independent studies) | LFA; - A latent factor(s) is/are posited to underlie a set of observed, continuous variables; - Must test the invariance of the latent factor(s) when comparing across groups | - Methodology well known; - As long as there is a subset of invariant items, the factor can be combined across studies; - Can include noncommon items in analyses; - Even if no items are common to all studies, can still be conducted if studies can be “chained” together. For example, if item sets A and B are available in study 1, item sets B and C are available in study 2 and item sets C and D are available in study 3 | - The validity of the results is dependent on the method used to identify the model. For example, the use of the reference item method (i.e., constraining the intercept and loading of one item to 0 and 1 in both groups) implicitly assumes the reference item is invariant across groups. Another option is to set the factor mean and variance to 0 and1 in one group then estimate factor mean and variance in the other group while placing equality constraints on one or more item intercepts and loadings. This second procedure only works well when the number of noninvariant items is small relative to the number of invariant items; - Requires continuous indicators; - Requires more than one common item to measure equivalence; - Sample units must be independent of one another (i.e., no repeated measures)
Bauer, DJ. 2009^70^ | Two-parameter logistic (2-PL) using Item response theory (IRT) | | 2-PL IRT; - Assumes a single latent trait underlies a set of binary responses. Some items may be more difficult than others and some items may be more strongly related to the latent trait than others. Each item is assumed to have a conditional Bernoulli distribution including discrimination and difficulty parameters; - It is typically assumed the latent trait has a standard normal distribution | - Widely used methodology (especially in testing); - As long as there is a subset of invariant items, the factor can be combined across studies; - Can include noncommon items in analyses; - Even if no items are common to all studies, can still be conducted if studies can be “chained” together. For example, if item sets A and B are available in study 1, item sets B and C are available in study 2 and item sets C and D are available in study 3 | - Requires binary indicators. For example, it could be used to measures dimensions of psychopathology by using a set of symptoms indicators; - Requires more than one common item to measure equivalence; - Sample units must be independent of one another (i.e., no repeated measures)
Bauer, DJ. 2009^70^ | Moderated nonlinear factor analysis (MNLFA) | | MNLFA Uses generalized factor analysis models that can incorporate binary, ordinal, continuous and count items. The key parameters of the factor model (i.e., the indicator intercepts, factor loadings, and factor mean and variance) are permitted to vary as a function of one or more exogenous variables | - Can accommodate different scale types among items | - Requires more than one common item to measure equivalence; - Sample units must be independent of one another (i.e., no repeated measures)
Burns, RA. 2011^71^ | Multiple Imputation | Combining MMSE scores with missing data across 9 Australian longitudinal studies of aging (Dynamic Analyses to Optimize Aging [DYNOPTA] project) Participants missing at least one MMSE item varied greatly by contributing study and wave of data collection [range 0.5%–95%] Missing information related to demographic characteristics, especially age and education | MI used imputer model in multiple imputation with chained equations (MICE). The model included: gender, years of education, study and study interactions. Created 5 imputation datasets and took the average of the 5 imputed plausible values Software: MICE add-on to STATA version 10 | - Does not require special software to run MICE subsequent analyses (i.e., one final dataset with average values); - Compared with single imputation methods, MI accounts for uncertainty in the missing value by using a set of plausible values | - Requires the same measures across studies; - Requires item level data
Gorsuch, R. 1997^72^ | Extension analysis in exploratory factor analysis | In exploratory factor analysis extension analysis refers to computing the relationship among common factors to variables that were not included in the factor analysis. For example, this would be used in a situation where a factor analysis would include proven items but now new experimental items. | A factor analysis is conducted on the core variables. The correlations between the core variables and the extension variables to estimate the factor pattern of the extension variables with the factors derived from the core variables. | - Widely used methodology | - Requires the core set of variables to be common to all studies; - Requires the extension set of variable to be common to all studies; - Only appropriate for continuous variables
McArdle, JJ. 2009^73^ | IRT combined with latent growth/decline curve modeling | This method was applied to longitudinal data from different cognitive test batteries to examine how to best model changes in cognitive constructs over a life span. The data come from 3 classic studies on intellectual abilities (Berkeley Growth Study (BGS), Guidance–Control Study (GCS), and Bradway–McArdle Longitudinal (BML) Study). In total, 441 persons were repeatedly measured as many as 16 times with age at measurement ranging from 2 to 72 years. Vocabulary data were analyzed for 419 participants and memory data were analyzed for 416 participants. The cognitive constructs measured were vocabulary and memory using 8 different intelligence test batteries (1916 Stanford–Binet (SB), SB Form L, SB form LM, Wechsler–Bellevue (WB) Intelligence Scale Form I, Wechsler Adult Intelligence Scale (WAIS), WAIS-Revised, and the Woodcock–Johnson (WJ) Psycho-Educational Battery–Revised). Although the tests were common items among the tests, different tests were between studies and over time within studies. All three studies include participant from the Bay area of California. | The authors consider several techniques for linkage across measurement scales and across multiple groups and fit a unidimensional Rasch model to item responses and a latent curve model together with changing latent scores over age and groups. The latent growth/decline curve model had a separate within-time measurement equation and over-time functional change equation. Because some items used in these analyses have graded outcome scores (i.e., 0, 1, or 2), a partial credit model was used for the IRT model. The parameters of both IRT and latent curve models were simultaneously estimated based on a joint model likelihood approach | - Can be used without complete overlap of items; - Items can be linked by data (i.e., bridge studies and bridge items), by assuming equivalence, or by a combination of the two; - Allows for a varying number of data points per person; - Allows instruments to change over time within an individual; - Method allows one to separate out differences in scales over time from changes in constructs over time | - Requires overlapping information across studies
Minicuci, N. 2003^74^ | Multiple methods including recategorization and z-score transformations | Constructed a harmonized measures using data from six countries [Finland, Italy, the Netherlands, Spain, Sweden and Israel] contributing data to the Comparison of Longitudinal European Studies on Aging (CLESA) Study. The first goal of the study was to create a common data base (CDB) with a framework to include behavioral, social, psychological, and health status measures. A common measure was created if at least 3 countries had measured the construct of interest (this led to the creation of different harmonized options for the same construct). The CDB is a harmonized file containing 11,557 records and 111 variables on socio-demographic characteristics, health habits, health status, physical functioning, social networks and support, and health and social service utilization | For each type of variable, harmonization guidelines were developed including: the definition and variable names of the standardized measures and their modalities and relative coding; a list was made of the name of the original variable(s) for each country, with their original modalities; and the algorithm used to obtain the harmonized variables from the original variables When harmonization was deemed appropriate, the most common methods for harmonization were to recategorize variables into a common set of response option and to create a common scale, e.g., 0–1, by dividing a continuous score by its maximum score Another related method of conversion is to create z-scores for each construct by subtracting the overall mean and dividing the raw score by the standard deviation. | - Relatively simple and does not require specialized statistical software; - Does not require any common items across studies | - Does not take into account the difference in distributions/variability across populations; - Assumes the underlying constructs are the same and measured equally well across populations
Gross, A. 2012^75^ | Mean, linear, and percentile transformations | Constructed mean, linear and percentile equating using data from two large-scale, multi-site cohorts: the Advanced Cognitive Training for Independent and Vital Elderly (ACTIVE) and the Alzheimer’s Disease Neuroimaging Initiative (ADNI). ACTIVE is a longitudinal randomized trial of cognitive training in cognitively intact, community dwelling adults age 65 and older ADNI was a five-year observational cohort study of Alzheimer’s disease (AD), with the primary goal of assessing the extent to which serial magnetic resonance imaging, positron emission tomography, other biological markers, and cognitive tests can be used to predict progression to mild cognitive impairment (MCI) and AD | Used a two stage approach. In the first stage, an equating sample was selected from which to collect necessary characteristics of test distributions and derive the equating algorithm. In the second stage, equating algorithms were applied to the full study sample in a way that preserved attrition, aging, cohort, and group differences but eliminated form differences. Equated scores were then compared visually using plots of mean recall over time and cumulative probability plots and statistically using tests of equivalence of means in reference groups as well as estimates of within-person change using latent growth models. | - Can be used with longitudinal data; - Can be used to adjust | - Assumes that the population producing responses on different scaled tests at each time point have the same underlying ability; - Linear equating assumes normally distributed variables (not a limitation for equipercentile equating); - Outcome must be continuous
van Buuren, S. 2005^76^ | Response conversion (RC) | This method was applied to binary and original data measuring walking disability measured across 10 European countries. | RC is a two-step method. The first step is to construct a conversion key using a statistical model (e.g., polytomous Rasch model). This step models the relationship between the common scale and the measured items. The second step uses a conversion key to convert information onto a common scale | - Can be used without complete overlap of items; - Items can be linked by data (i.e., bridge studies and bridge items), by assuming equivalence, or by a combination of the two | - Requires overlapping information across studies

2PL-IRT = two-parameter logistic using item response theory; BGS = Berkeley Growth Study; BML = Bradley-McArdle Intelligence Scale; CDB = common database; CLESA = Comparison of Longitudinal European Studies on Aging; DYNOPTA = Dynamic Analyses to Optimizing Ageing; GCS = Guidance-Control Study; IRT = item response theory; LFA = linear factor analysis; MI = multiple imputation; MICE = multiple imputation with chained equations; MMSE = Mini Mental State Examination; MNLFA = moderated nonlinear factor analysis; RC = response conversion; SB = Stanford-Binet; WAIS (-R) = Wechsler Adult Intelligence Scale (Revised); WB = Wechsler-Bellevue; WJ = Woodcock Johnson Psycho Educational Battery-Revised

Table 3 Summary of supplemental articles on individual participant data meta-analysis and methods to support statistical harmonization

Topic | Citation | Summary
General articles on conducting IPD | Blettner, M. 1999^77^ | - Described the strengths and limitations of four methods of summarizing data: qualitative summary, meta-analysis of published data, re-analysis of IPD, and prospectively planned pooled analyses; - Harmonization of data not mentioned
General articles on conducting IPD | Cooper, H. 2009^78^ | - Discussed the relative merits of conducting an IPD vs. aggregated data (AD) analysis; - IPD permits subgroup analysis and quality assurance of the original analysis reported in the literature, but is more costly
General articles on conducting IPD | Curran, PJ. 2009^79^ | - Discussed issues around conducting integrative data analysis (IDA) as defined as the statistical analysis of a single data set that consists of two or more separate samples that have been pooled into one; - Identified two possible methods to deal with heterogeneity due to measurement: nonlinear factor analysis (NFA) and item response theory (IRT); - They recognize the issue of combining complex constructs, such as depression, but they do not provide detailed information on how to handle this issue in pooling data from different studies
General articles on conducting IPD | Friedenreich, CM. 1993^86^ | - Presented a methodology for the pooling and analysis of epidemiologic studies using individual subject level data; - Discussed random and fixed effect models, examining homogeneity of effects, explaining any heterogeneity, sensitivity analyses and quality assessment
General articles on conducting IPD | Ioannidis, JPA. 2002^80^ | - Discussed advantages and disadvantages of IPD meta-analysis of time to event data in genetic epidemiology; - Standardization of information across studies using a priori definitions was listed as an advantage as a standardized set of variables was available for all studies; - Other issues around harmonization were not mentioned
General articles on conducting IPD | Riley, RD. 2010^2^ | - Discussed the rationale, conduct and reporting of IPD meta-analyses; - Did not discuss the issue of different variables/measures being available among datasets
General articles on conducting IPD | Schmid, CH. 2003^81^ | - Discussed issues around conducting an IPD analysis using data from multiple international RCTs evaluating the effect of ACE inhibitors for treatment of nondiabetic renal disease
General articles on conducting IPD | Simmonds, MC. 2005^82^ | - Reviewed methods used to conduct IPD meta-analyses conducted during 1999–2001.; - Harmonization of data not mentioned
General articles on conducting IPD | Van der Steen, JT. 2008^83^ | - Discuss benefits and pitfalls of pooling databases from comparable observational studies of lower respiratory infection in nursing home residents in the U.S. (Missouri) and the Netherlands (Amsterdam); - Identified issues in comparability in measurements in terms of: 1) question wording and response options, 2) clinical meaning, 3) response distributions; - If response distributions to the same question differed by population, they tried to do qualitative interviews with physicians to determine whether the variable had a different meaning between the countries; - Did not discuss specific methodology for constructing new variables when differences there were differences between the variables in the two databases
General articles on conducting IPD | van Walraven, C. 2010^84^ | - Discussed reward and challenges of IPD meta-analysis.; - Reward: outcome and analytical harmonization; - Challenge: getting and harmonizing data
IPD analysis Methods | Bennett, DA. 2003^85^ | - Reviewed analytic methods for prospective cohort studies using time to event data for single studies and IPD meta-analyses; - Discussed issues around missing data (event times and covariates) for individual studies as well as for IPD meta-analyses; - Suggested running a simulation sensitivity analysis to determine the extent of biasing and underestimation of standard errors using different methods for imputation of event times; - In their example, the authors did not employ imputation methods for covariates due to the size of the data set; - The authors reported the number and nature of the missing covariate values according to key variables such as cohort, censoring status, age at recruitment.
IPD analysis Methods | Granda, P., Blasczyk, E. 2010^8^ | - Defined general approaches to harmonization; - Input harmonization aims to achieve standardizes measurement processes and methods in all national or regional populations; - Output harmonization uses different national or regional measurements possibly derived from nonstandard measurement tools; - An ex-post strategy to output harmonization (i.e., surveys made comparable after the fact, retrospective harmonization) requires a conversion process; - This conversion process should be transparent, well documented, and reversible; - Focus should be given to both variable level and survey level harmonization; - Need to develop criteria to assess the quality of harmonization
IPD analysis Methods | Granda, P., Wolf, C., Hadorn, R. 2010^69^ | - Discussed strategies and issues around harmonization of survey data; - Provided methods for assessing the quality of harmonization or the degree to which the original information is preserved in the harmonized data; - This is most applicable to direct harmonization (i.e., when a single harmonized variable is created directly a single questionnaire item)
IPD analysis Methods | Hofer, SM. 2009^87^ | - Discussed the challenges of meta-analytic and pooled data approaches using cognitive aging literature as an example; - Discussed concurrent calibration (cocalibration) of data using IRT models or with latent variable approaches based on item- or scale-level data across studies; - Feasibility of pooling variable is limited when variables are not operationally defined in the same way; - Using standardized variables (T scores) or proportion correct requires assuming the measurement properties of the variables are relatively comparable and linear; - Also need to consider population characteristics such as age, birth cohort, education ranges; - Proposed a coordinated analysis approach to enhance communication and collaboration among researchers, facilitate reproducible research, archive analysis and measurement alignment process, to provide a stronger basis for cumulative science, and to permit quick entry into completed analyses
IPD analysis Methods | Jones, AP. 2009^88^ | - Discussed methods used to combine longitudinal clinical trial data across studies using IPD and aggregate data methods; - Did not discuss the issue of different variables/measures being available among datasets
IPD analysis Methods | Mathew, T. 2010^89^ | - Compared One-step (linear function of the mean obtained from a linear model of IPD) vs. Two-step (linear function of the mean obtained from linear model of summary data) meta-analysis models using IPD; - It provides a nice overview of IPD meta-analysis; - Did not discuss the issue of different variables/measures being available among datasets
Comparison of imputation methods | Burgess, S. 2011^90^ | - Described four Bayesian methods for imputing missing data based on a missing at random (MAR) assumption in the context of genetic epidemiology: multiple imputations, single nucleotide polymorphism (SNP) imputation, latent variables, and haplotype imputation; - Results of a simulation study and application to the British Women’s Heart and Health Study were presented; - Method analogous to the 2-stage least-squares method except it accounts for the observational correlation between phenotype and outcome. This analysis was done using WinBUGS; - Precision was improved using four imputation methods—equivalent to 25% increase in sample size; - All imputation methods give similar results
Comparison of imputation methods | Donegan, S. 2010^91^ | - Reviewed the reporting and methodological quality of indirect comparisons (which could be considered an extreme missing data situation); - Authors conducted a systemic review including 43 reviews in which clinical effectiveness of two interventions were indirectly compared; - In general, the underlying assumptions of conducting an indirect comparison analysis were not routinely described or tested
Comparison of imputation methods | Peyre, H. 2011^92^ | - Compared imputation method for data Missing Completely at Random (MCAR), Missing at Random (MAR), and Missing Not at Random (MNAR) within one study; - Methods compared: personal mean score (PMS), multiple imputation (MI), hot deck (HD) imputation and full information maximum likelihood (FIML); - MI and FIML superior to PMS and HD in terms of accuracy and precision; - HD tended to underestimate and PMD associated with insignificant bias
Comparison of imputation methods | Siddique, J. 2011^93^ | - The authors used an imputation approach to calibrate rater bias in the diagnostic assessment of posttraumatic stress disorder (PTSD); - Nurse practitioners were twice as likely to diagnose PTSD than a clinical psychologist—and each patient was randomly assigned to be rated by only one rater; - A Bayesian random effects censored ordinal probit model was used to identify a latent moderate class of patients; - A Markov chain Monte Carlo algorithm was used to estimate the posterior distribution of the model parameters and generate multiple imputations for the recalibrated diagnosis variable
Comparison of imputation methods | Spratt, M. 2010^94^ | - Examined how the choice of imputation model and the number of imputations affected estimates of prevalence and associations in a study of wheezing among 81-month-old children in Avon Longitudinal Study of Parents and Children; - Preliminary analyses of the association of measured variables with missingness and outcome variables are required to determine the plausibility of the assumptions underlying both complete-case and multiple-imputation-based analyses.; - They applied a covariate (socioeconomic status) which was available on all subjects as an intermediate variable to generate multiple imputations procedures; - Analyses of MI should often be based on 25 or more imputed values in order to reduce the impact of random sampling inherent in the MI process
Comparison of imputation methods | Sterne, JAC. 2009^95^ | - Reviewed the reasons why missing data may lead to bias and loss of information; - Discussed situations in which multiple imputation may help reduce bias and increase precision as well as the potential pitfalls; - Proposed guidelines for reporting analyses using multiple imputation
Methods for evaluating equivalence | Crane, PK. 2008^96^ | - Compared item- and scale-level strategies for handling demographic heterogeneity when measuring executive function; - Examined the extent to which item-level and scale-level adjustment for demographic variables influenced the relationships with various composite executive function scores with an external criterion (MRI); - The authors created composite scores for executive function using classical test theory and item response theory in which demographic differences were ignored or taken into account; - Candidate scores were compared using 3 linear regression models; model A included demographic terms as independent variables, model B include MRI variables, and model C included both; - R^2^ was used to estimate effect sizes
Methods for evaluating equivalence | Teresi, JA. 2007^97^ | - Discussed methods based on IRT that can be used to examine differential item functioning (DIF) within study subgroups; - The method used was the item response theory log-likelihood ratio (IRTLR) approach; - This method could also be extended to testing DIF among study populations

ACE = angiotensin-converting-enzyme; DIF = differential item functioning; FIML = fill information and maximum likelihood; HD = hot deck; IDA = integrative data analysis; IPD = individual patient data; IRT = item response theory; IRTLR = item response theory log-likelihood ratio; MAR = missing at random; MCAR = missing completely at random; MI = multiple imputation; MNAR = missing not at random; MRI = magnetic resonance imaging; NFA = nonlinear factor analysis; PMS = personal mean score; PTSD = post traumatic stress disorder; RCT = randomized controlled trial; SNP = single nucleopeptide polymorphisms; U.S. = United States of America

Table 4 Examples of studies presenting harmonized data

Topic | Citation | Summary
Examples of analyses of harmonized data | Anstey, KJ. 2010^98^ | - Harmonized data from the Dynamic Analyses to Optimizing Ageing (DYNOPTA) project; - Harmonized data [including cognitive measures] from 9 Australian cohorts using response conversion (see van Buuren above); - Did not give details on the analysis
Examples of analyses of harmonized data | Bath, PA. 2010^99^ | - Harmonized data from the Longitudinal Aging Study Amsterdam (LASA) and the Nottingham Longitudinal Study on Activity and Ageing (NLSAA) [including cognitive measures]; - LASA used the Mini Mental State Exam (MMSE: 30 point scale) and the NLSAA used the Clifton Assessment Procedures for the Elderly (CAPE: 12 point scale); - The derived variables were simply MMSE/30 and CAPE/12
Examples of analyses of harmonized data | Beer-Boorst S. 2000a100 Beer-Boorst, S. 2000b101 | - Developed a common surveillance system to allow for the comparison of lifestyle and biological risk factors from different populations across Europe including seven collaborating centers [European Alimentation (EURALIM)]; - Common variables included: diet, health, lifestyle and demographic variables; - Did not discuss method of harmonization
Examples of analyses of harmonized data | Crane, PK. 2008^102^ | - Used IRT to cocalibrate cognitive scales from three large community-based studies (the Cardiovascular Health Study [CHS], the Adult Changes in Thought Study [ACT] and the Indianapolis site from the Indianapolis-Ibadan Dementia Project; - The primary objective was to cocalibrate the Mini Mental State Examination (MMSE), Modified Mini Mental State Exam (3MS), Cognitive Abilities Screening Instrument (CASI), and The Community Screening Instrument for Dementia (CSI ‘D’); - Used McDonald’s bifactor model to evaluate whether the scales were unidimensional; - Identified anchor items that were comparable across tests—only included identical items (e.g., interlocking pentagons); - Used Samejima’s graded response model to estimate the probability of each response category for each item for any level of cognitive functioning. This formula was used to determine the most likely response for every cognitive functioning level
Examples of analyses of harmonized data | Curran PJ. 2008^103^ | - Used IRT to fit a series of growth curve models to a single pooled sample that consists of data drawn from three separate studies of developmental internalizing symptomology; - The studies examined children with and without alcoholic parents (The Michigan Longitudinal Study [MLS], the Adolescent/Adult Family Development Project [AFDP], and the Alcohol and Health Behavior Project [AHBP]); - There were 21 unique dichotomous self-report items to define internalizing symptomology; four items were present in all studies; - Dimensionality Step: Factor analysis was used to examine the dimensionality of the 21 items by conducting an exploratory factor analysis in each study to assess unidimensionality based on traditional measures including eigenvalues, scree plots and estimates of incremental variance; - Calibration Step: Fitted a standard 2PL IRT model to the 21 dichotomous items from a single randomly selected assessment for each participant in the pooled sample; - DIF Step: Estimated a series of multiple group IRT models as a function of developmental status, gender and study group membership; - Scoring Step: calculated individual time-specific scale scores for every participant at every time point at which they were assessed using a modal a posteriori method.
Examples of analyses of harmonized data | Darby S. 2006^104^ | - Authors used data from 13 studies of residential radon and lung cancer carried out in Europe (Austria, the Czech Republic, Finland [2], France, Germany [2], Italy, Spain, Sweden [3], and the UK); - Data were assembled according to a common format and uniform definitions were used except for study-specific definitions for social status [did not detail how this was put into a common metric]; - Data were analyzed using a linear odds model; models were fit using conditional maximum likelihood (similar to conditional logistic regression)
Examples of analyses of harmonized data | The Fibrinogen Studies Collaboration. 2009^105^ | - The authors combine data on the association between plasma fibrinogen and coronary heart disease in 31 cohort studies using proportional hazards (Cox) model, stratified by cohort, sex and (for the two RCTs) trial arm; - All studies provided data on fibrinogen level, age, smoking status, total cholesterol, SBP and BMI; - Some studies also provided data on HDL and LDL cholesterol, alcohol consumption, triglycerides and history of diabetes; - The authors use a two-stage process. At the first stage partially and (where possible) fully adjusted estimates are obtained from each study, together with their standard errors (a key issue is estimating the within study correlation of the two estimates); - At the second stage, the results are combined in a bivariate meta-analysis; - This study addresses the issue of when studies included in an IPD meta-analysis include some, but not all, important confounding variables; - The proposed bivariate model, with estimates of the parameter of interest either fully or partially adjusted for confounding factors may be useful also for more difficult constructs. Some studies measuring the construct fully and other studies measuring the construct only partially could possibly analyzed with this bivariate approach
Examples of analyses of harmonized data | Grimm KJ. 2010^106^ (see also Duncan, GJ. 2007^107^ | - The authors examined the associations between early behavioral and cognitive skills with later achievement using data from 3 longitudinal studies (the NICHD Study of Early Child Care and Youth Development [SECCYD], the National Longitudinal Survey of Youth–Children and Young Adults [NLSY-CYA], and the Early Childhood Longitudinal Study Kindergarten Cohort [ECLS-K]); - Behavior scales differed among the studies and categorization of children into “normative”, “problematic” and “clinical” groups was done using set cut-offs or based on the observed distribution of the data (e.g., T-scores); - The authors used a combined item-response and growth curve model to account for differential reliability
Examples of analyses of harmonized data | Khachaturian, AS. 2010^108^ | - The authors describe the challenges and opportunities for developing a national database for successful aging; - One of the main challenges is defining a “case” for population-based prevention studies; - Clinical assessment conducted by experts produce accurate diagnoses, but are very costly, labor intensive and require highly trained personnel; - Population studies, because of a lower yield, necessitates greater efficiency and lower-cost less-highly trained personnel; - Need for multi-stage assessment among subject, other informants (e.g., family members), as well as clinical assessments by clinicians and nonclinicians (including surveys by mail and telephone cognitive assessments); - The critical questions identified were: 1) can these assessment approaches be refined in order to detect or predict individuals who may develop future impairments, or declination, in cognition or behavior, or even scaled down for high volume throughput; 2) can technologies be developed to allow the most passive, nonintrusive assessment of the individual’s cognitive and behavioral function; and 3) will the collected longitudinal data afford the possibility to measure intra-person change, vis-a-vis Bayesian-modeling approaches; - The issue of measuring within-person change over time was also highlighted as the ultimate aim is to predict the trajectory of an individual’s cognitive-behavioral-functional health, the rate of decline, and the point at which one crosses the threshold from an asymptomatic stage to a phenotype resembling pre-MCI, then to MCI, and then to AD
Examples of analyses of harmonized data | McArdle, JJ. 1998^109^ [see also McArdle, JJ. 1994;110 McArdle, JJ. 1997^111^] | - The authors use methods based on linear structural equations models with incomplete or missing data to analyze longitudinal twin data for two cognitive variables to evaluate a biometric genetic hypothesis in the context of a developmental model of intellectual growth and change (biometric genetic analysis of intellectual abilities [BGIA]); - In this study, the same measurement scales (block design and vocabulary measures) were used over time, however the number of observations, the age at first administration, and the interval between administrations differed within the twin pairs and among the sets of twins. The raw scores were transformed into percentage-correct scales (0–100).; - The authors used all available data, including participants with incomplete and possibly nonrandomly missing data; - The authors incorporated a twin analysis including means and age effects; a longitudinal analyses based on latent growth components; and a biometric-genetic analyses for components of growth using linear structural equations models
Examples of analyses of harmonized data | Minicuci, N. 2011^112^ | - Compared measures of Disability Free Life Expectancy (DFLE) across different surveys conducted in Bulgaria (National Health Interview Survey [NHIS]), Italy (Multidisciplinary Survey among Italian Families [IMF-S]) and Latin America (the Salud, Bienestar y Envejecimiento [SABE]); - Harmonized 5 ADL questions common to all surveys; - Dichotomized responses to create a common scale
Examples of analyses of harmonized data | Pluijm, SMF. 2005^113^ | - Constructed a harmonized measure of ADL using data from six countries contributing data to the Comparison of Longitudinal European Studies on Aging (CLESA) Study; - There was overlap in the ADL items among countries, but only 2 of the 11 possible items were asked in all surveys; - Items that were incompatible across countries because of cultural differences were excluded from the harmonization process; - Harmonization focused on the four items comprising the Katz ADL index; all four items were present in four of the six country surveys; five- and six-item scales were constructed in the countries that had the additional items in common; - In countries where the two items were not measured, the data for these was extrapolated from other “comparable” ADL items; - Because they used different response options among the surveys all items were dichotomized to put them on a consistent scale; - Subjects were excluded if 2 or more items were missing; hot deck methods were used to impute values when one of the items was missing due to nonresponse; - Reliability and validity of the four item scale was assessed
Examples of analyses of harmonized data | Ruggles, S. 2003^114^ Esteve, A. 2003^115^ | - The Integrated Public Use Microdata Series (IPUMS)-International involved working with census data from different time periods and institutional origins; - The first stage of harmonization involved standardizing the data formats and correcting errors; - The second stage of harmonization involved harmonizing the codes for all variables across datasets; - Variable-level harmonization involved recoding variables to maximize comparability across datasets.; - In this example, the content included among the datasets was greatly overlapping, but different numeric classification systems were used
Examples of analyses of harmonized data | Schenker, N. 2007^116^ | - The authors describe several situations in which data from multiple surveys were used to enhance estimation of measures of health; - The four projects involved: (1) combining estimates from a survey of households and a survey of nursing homes to extend coverage; (2) using information from an interview survey to bridge the transition in race reporting in the United States census; (3) combining information from an examination survey and an interview survey to improve on analyses of self-reported data; and (4) combining information from two interview surveys to enhance small-area estimation; - In project 3, the authors discussed methods for combining information from two surveys conducted by the National Center for Health Statistics to improve on analyses of self-reported data on health conditions; - One of the surveys, the National Health and Nutrition Examination Survey, was unusual in that it not only asked self-report questions on health conditions during face-to-face interviews, but it also obtained clinical measures based on physical examinations; - The other survey, the National Health Interview Survey, was larger, and it obtained a rich set of variables for use in multivariate analyses, but it relied on self-report questions for its information on health conditions; - ‘Measurement error’ models that predict clinical outcomes from self-reported answers and covariates were fitted to data from the National Health and Nutrition Examination Survey, and the fitted models were then applied to data from the National Health Interview Survey to adjust for possible inaccuracies due to self-reporting; - Multiple imputation was used to properly reflect the sources of variability in subsequent analyses
Examples of analyses of harmonized data | Slimani, N. 2002^117^ | - Harmonized data from 10 Western European countries (Denmark, France, Germany, Greece, Italy, Norway, Spain, Sweden, The Netherlands, UK) which from the European Prospective Investigation into Cancer and Nutrition (EPIC) project; - Information on usual individual dietary intakes was obtained using different dietary assessment methods developed and validated in each participating country; - A calibration approach was adopted to adjust for possible systematic over- or underestimation in dietary intake measurements and correct for attenuation bias in relative risk estimates; - A single 24-hour dietary recall was collected from a random sample of 5–12% (1.5% in the UK) of the EPIC cohorts, weighted according to the cumulative number of cancer cases expected per fixed age and sex stratum; - Standardized software (EPIC-SOFT) was developed to assess dietary intake reported across the EPIC centers
Examples of analyses of harmonized data | van Buuren, S. 2003^118^ Hopman-Rock, M. 2000^119^ | - Used response conversion to harmonize international disability information from ERGOPLUS (Rotterdam) and EURIDISS (3 countries in Europe); - The first step was to create a conversion key; used Rasch modeling (a partial credit model) to estimate the parameters for the conversion key; - The second step involved the conversion of the observed data onto the common scale

2PL IRT = two-parameter logistic using item response theory; 3MS = Modified Mini Mental State Exam; ACT = Adult Changes in Thought Study; AD = Alzheimer’s disease; ADL = activities of daily living; AFDP = Adolescent/Adult Family Development Project; AHBP = Alcohol and Health Behavior Project; BGIA = biometric genetic analysis of intellectual abilities; BMI = body mass index; CAPE = Clifton Assessment Procedures for the Elderly; CASI = Cognitive Abilities Screening Instrument; CHS = Cardiovascular Health Study; CLESA = Comparison of Longitudinal European Studies on Aging; CSI ‘D’ = Community Screening Instrument for Dementia; DFLE = Disability Free Life Expectancy; DIF = differential item functioning; DYNOPTA = Dynamic Analyses to Optimizing Ageing; ECLS-K = Early Childhood Longitudinal Study Kindergarten Cohort; EPIC = European Prospective Investigation into Cancer and Nutrition; EURALIM = European Alimentation; HDL = high-density lipoprotein; IMF-S = Multidisciplinary Survey among Italian Families; IPD = independent patient data; IPUMS = Integrated Public Use Microdata Series; IRT = item response theory; LASA = Longitudinal Aging Study Amsterdam; LDL = low-density lipoprotein; MCI = mild cognitive impairment; MLS = Michigan Longitudinal Study; MMSE = Mini Mental State Examination; NHIS = National Health Interview Survey; NLSAA = Nottingham Longitudinal Study on Activity and Ageing; NLSY-CYA = National Longitudinal Survey of Youth-Children and Young Adults; RCT = randomized controlled trial; SABE = Salud, Bienestar y Envejecimiento; SBP = systolic blood pressure; SECCYD = NICHD Study of Early Child Care and Youth Development; UK = United Kingdom

There were three general classes of statistical methods identified in this scan. One class used a simple linear- or z-transformation to create a common metric for combining constructs measured using different scales across datasets. A summary of the assumptions and the application of this type of model is in Table 5. An example of this class is in the Comparison of Longitudinal European Studies on Aging. When harmonization was deemed appropriate, some constructs were converted to a 0 to 1 scale by dividing a continuous score by its maximum score.

Table 5 Assumptions for the different classes of statistical harmonization methods

Method | Assumptions | How Can It Be Applied
Standardization Methods 6 studies used this class of methods, e.g., Minicuci, N. 2003^74^ | - Scales have an underlying normal distribution; - The scales have a similar distribution (i.e., being in the 5^th^ percentile of one scale is equivalent to being in the 5^th^ percentile of another) | Can be applied in most situations with continuous variables and does not require specialized software Does not require common items across studies Need to transform back to a chosen scale(s) for interpretation
Item Response Theory Latent Variable Model 15 studies used this class of methods, e.g., Van Buuren, S. 2005;^76^ Bauer, DJ. 2009;^70^ McArdle, J. 2009^73^ | - Underlying constructs are unidimensional; - Some items must be common across datasets or at least can be “chained” together; - The items are equally discriminating (only for IP and Rasch models); - Factorial invariance; If repeated measures:; - Item difficulty is invariant with respect to time or age; - Item discrimination does not change across time or age | Can be applied to continuous, binary and ordinal data but requires some specialized software Can accommodate different scale types among items However can be extended to include longitudinal data as per McArdle, et al. by integrating IRT and latent curve modeling using a joint model likelihood approach
Missing data by design with multiple imputation 3 studies used this class of methods, e.g., Burns, RA. 2011^71^ | - Missingness is assumed to be at random (i.e., MAR); - Some items must be common across datasets or at least can be “chained” together | Can be applied to continuous, binary and ordinal data but requires some specialized software and multiple datasets Can accommodate different scale types among items Can be used if scales are not unidimensional

IRT = item response theory; MAR = missing at random

A second class of methods posits that there is a latent factor(s) that underlies a set of measured items that can be modeled using linear factor analysis (if the items are continuous), two parameter logistic item response theory (if the items are binary), or a polytomous Rasch model (if the items are ordinal), or moderated nonlinear factor analysis (MNFA) if there is a mix of binary, ordinal, and/or continuous items. These methods are described in the articles by van van Buuren, et al.,76 Bauer, et al.,70 and Gorsuch.72 In each case, the first step is to construct a “conversion key” using one of the statistical models described above. This step models the relationship between the latent construct and the measured items. The second step uses the conversion key to convert the information onto a common scale. Measurement equivalence must then be assessed across samples.97

The MNFA method proposed by Bauer is the most generalizable as it can accommodate different types of item data—binary, ordinal, or continuous—within a single model.70 All of these approaches require that items can be “chained” together among studies, such that each study must have at least some items that overlap with another study. Another potential limitation is that the methods require independent data within studies and may not be appropriate for repeated measures in a longitudinal study. The authors using these methods tended to randomly choose one observation per person if more than one was available in the dataset. The methods proposed by van Buuren76 and Bauer70 are described in detail in Table 6.

Table 6 Overview of some approaches for harmonization of constructs

Van Buuren S, Eyres S, Tennant A, Hopman-Rock M, Improving comparability of existing data by response conversion, Journal of Official Statistics, 2005, 21(1), 53–72.^76^
- Focus is on health surveys using questions with ordinal categories; - Construct of interest is “walking disability” but the approach is applicable also to other constructs; - Incomparability of data occurs when questions on the same construct are not identically formulated over different studies. Example of incomparability; UK Health survey:; How far can you walk without stopping/experiencing severe discomfort, on your own, with aid if normally used?; 1. can’t walk; 2. a few steps only; 3. more than a few steps; 4. less than 200 yards; 5. 200 yards or more; Dutch Health survey; Can you walk 400 meters without resting (with walking stick if necessary)?; 1. yes, no difficulty; 2. yes, minor difficulty; 3. yes, major difficulty; 4. no; - The approach of harmonization requires at least one “bridge variable”, which is a question that is comparable over two studies. Linking m studies requires at least one bridge variable, when all studies include this question, and at most m-1 bridge variables, when only one unique bridge variable is available between two studies.; - Two studies with 306 and 292 participants, respectively, were used to illustrate their harmonization method of “response conversion”. Three questions on walking disability were used for illustration: SI01, HAQ8, and GAR9. The HAQ8 is the bridge variable, while SI01 is only observed in one study and GAR9 is only observed in a second study.
SI01: | I walk shorter distances or often stop for a rest 0 = no 1 = yes
HAQ8: | Able to walk outdoors on flat grounds 0 = without any difficulty 1 = with some difficulty 2 = with much difficulty 3 = unable to do so
GAR9: | Can you, fully independently, walk outdoors (if necessary with a cane)? 0 = yes, no difficulty 1 = yes, with some difficulty 2 = yes, with much difficulty 3 = no, only with help from others
- A latent variable (Rasch) model was selected to describe the outcome probabilities for these three questions. Let Y_hij_ be the ordinal response for question or item j (=SI01, HAQ8, GAR9), observed in study h (=1,2) for participant i (=1,2,…,n_h_). Note that Y_1i3_ and Y_2i1_ are essentially missing for all participants in the corresponding study. The proposed model is referred to as the “conditional logit” model (see Agresti, 2002):; P ( Y_h i j_ = c ∣ Z_h i_ = θ ) = exp ( ∑_k = 0_^c^ ( θ - δ_j k_ ) ) / ∑_r = 0_^K_j_^ exp ( ∑_k = 0_^r^ ( θ - δ_j k_ ) ) , 1; with c = 0,1,.....,K_j_ the range of outcomes for item j, δ_j0_, δ_j1_,....., δ_jk_j__ the fixed item specific parameters, and Z_hi_ a random latent variable for participant i in study h. Conditionally on the latent variable Z_hi_ the items are considered independent.; The fixed item specific parameters require a constraint, since δ_j0_ is unidentifiable in this formulation. Indeed, both the numerator and denominator in (1) can be divided by the expression exp(θ − δ_j0_) which would exclude the parameter δ_j0_ from the formula. Thus one particular constraint is for instance δ_j0_ = 0. The article describes other constraints on the item specific parameters, but they seem awkward, since they involve a constraint on the latent variable.; - The article discusses several priors or distributions for the latent variable Z_hi_, but the preferred prior is the shifted lognormal distribution with mean 1, variance 0.5, and shift −5. The comparison of their choices of priors was somewhat strange, because these priors varied in mean and standard deviations. It seems more relevant to compare standardized priors to see the effect of the prior instead of the effect of location shift or scale differences. Furthermore, they did not discuss separate parameters in the priors for their different studies, which could have been useful for their “response conversion” and for their investigation of equivalence of items over studies (“tension coefficient”).; - Using model (1) and the selected prior, “response conversion” is now defined through the conditional expectation of the latent variable given the observed outcome of the item response. Essentially, for any item j (including the bridge variable), they calculate the conditional expectation E(Z_hi_ \| Y_hij_ = c) for each of the categories c = 0,1,.....,K_j_. Since the prior on the latent variable is independent of studies, the conditional expectation for the bridge variable is unique and independent of studies. The expected value of the latent variable is now; μ_h_ = E ( Z_h i_ ) = E ( E ( Z_h i_ ∣ Y_h i j_ ) ) = ∑_c = 0_^K_j_^ E ( Z_h i_ ∣ Y_h i j_ = c ) P ( Y_h i j_ = c ) / ∑_c = 0_^K_j_^ P ( Y_h i j_ = c ) . 2; When the probabilities P(Y_hij_ = c) are estimated from the observed frequencies of an item in the study, the estimated mean value μ̂_h_ for the items in the studies may all be different. Since all of these estimates represent the mean walking disability (in any of the items) they can be compared across studies without using the bridge variable. In a sense, the difference in mean walking disability demonstrates the heterogeneity in walking disability between studies.; This approach would provide different mean walking disability for different items within the same study. This means that different estimates in mean disability arise when different items from same study are determined. The authors explain that this is reasonable and that it can be expected from the technical details, but this could have been avoided by including a shift parameter in the prior (that would indicate the difference between studies). Both the fixed item specific parameters and this location shift in the prior could have been estimated simultaneously using maximum likelihood estimation. This would provide a systematic difference in the latent walking disability which is constant across studies whatever choice of items is used.; - Their case study is substantially more complicated, since they combine multiple studies with multiple bridge variables. The method section discusses no specific approaches to detect possible lack of fit of the model (differential item functioning), but this was investigated in the example. They came up with a “tension coefficient”, which investigates the equivalence of items across studies. More research is required to investigate the distributional aspects of this tension coefficient, or to compare it to other approaches.
Bauer DJ, Hussong AM, Psychometric approaches for developing commensurate measures across independent studies: traditional and new models, Psychological Methods, 2009, 14(2), 101–125.^70^
- The proposed approach is applicable to all types of scales (continuous, count, ordinal, binary) including combinations of scales for different items in one study.; - Construct of interest is “alcohol involvement in adolescences”, but it is applicable to any other construct. They mention for instance dimensions of personality and psychology.; - Harmonization is defined as recoding variables such that they are scored with identical values in each study.; Example: One study may collect categorical data on family income (<10,000; 10,000—19,999; etc.) while the other record the numerical value. A harmonized variable would be a value collected in categories. This is a minimal step in the approach but it is not considered sufficient since the numerical value could be underreported, while this may be less of an issue when family income is asked in categories. This type of difference in harmonized variables may also occur when interpretation of items is affected by region or placement of items among other items.; - They provide three approaches, two old methods and one new method. The old methods are linear factor analysis (LFA) for items with a continuous scale and 2-parameter item response theory (2P-IRT) for items in a binary scale. The new method, moderated nonlinear factor analysis (MNLFA) makes it possible to combine different scales and moderate the model parameters with subject and study covariates. These approaches require “common items”, which are identical or harmonized items for a construct that is available across studies.; The mathematical detail of the LFA and 2P-IRT were presented by the authors only for one study, but we will formulate them for multiple studies. It is assumed that studies share common items such that all studies are linked. When all items have the same type, these psychometric models can be used to make and test commensurate measures across studies.; - Linear Factor Analysis:; Let Y_hij_ be the continuous outcome for item j (=1,2,….,J_h_) of subject i (=1,2,….,n_h_) in study h (=1,2,…., H). The statistical model is; Y_hij_ = ν_hj_ + λ_hj_Z_hi_ + ε_hij_, 3; with ν_hi_ the intercept and λ_hi_ the factor loading for item j in study h, Z_h i_ ~ N ( μ_h_ , τ_h_^2^ ) the latent variable for subject i in study h, and ɛ_h i j_ ~ N ( 0 , σ_h j_^2^ ) the residual. The latent variable and the residuals are assumed independent and the outcomes for items at one subject are independent conditionally on the latent variable.; - Two types of constraints on the model parameters were presented, but it seemed that the authors preferred to fix the distributional parameters of the latent variable for one study, e.g., μ_1_ = 0 and τ_1_ = 1. They also defined strong factorial invariance and partial factorial invariance. The studies are strong factorial invariant when the item specific parameters for all the common items are independent of studies. When this would hold only for a subset of common items, it is referred to as partial factorial invariant. They suggest testing this with the likelihood ratio test. Their strategy is to start with assuming strong factorial invariance and then it relaxes the constraints on the item specific parameters one by one item, until no real model improvement is obtained. Several references were provided to support this procedure. The article gives the impression that “commensurate measures” across studies are only attainable when there is at least partial factorial invariance. Without partial factorial invariance (or strong factorial invariance) there is no way that the studies can be combined because the studies essentially measure something else. Difference in distributional parameters of the latent variable across studies indicates heterogeneity between studies.; - 2 parameter item response theory; The outcome Y_hij_ for item j (=1,2,….,J_h_) of subject i (=1,2,…., n_h_) in study h (=1,2,…., H) is now binary. The statistical model is; P(Y_hij_ = 1 \| Z_hi_ = θ) = exp(ν_hj_ + λ_hj_θ)/(1 + exp(ν_hj_ + λ_hj_θ)), 4; with all item specific parameters and latent variable the same as for the latent factor analysis. The authors presented an alternative parameterization, but it is similar to (4). Factorial invariance and approaches to testing item equivalence for common items are also approached in the same way as for LFA.; - Moderated nonlinear factor analysis (MNLFA); The LFA and 2P-IRT are examples of generalized linear mixed models (McCullagh and Nelder, 1989), which means that link functions are used to connect the distribution of the outcome variable for an item to a linear predictor of explanatory variable. Let Y_ij_ be the outcome for item j (=1,2,…., J) of subject i (=1,2,…., n). In this formulation the authors only assume common items across all studies. The data has been pooled and an index for study does not occur anymore since studies will be incorporated through dummy variables. The author’s mention that this restriction to common items is no limitation since uncommon items can be seen as missing data for some studies. This means that they can combine through indirect comparisons and/or use imputation. The model is now; E ( Y_i j_ ∣ Z_i_ = θ ) = g_j_^- 1^ ( ν_i j_ + λ_i j_ θ ) Z_i_ ~ N ( μ_i_ , τ_i_^2^ ) 5; with the link function g_j_ depending on the item j and the item specific parameters ν_ij_ and λ_ij_ and distributional parameters μ_i_ and τ_i_ depending on the subject i through subject and study specific variables x_1i_, x_2i_,…., x_Qi_:; ν_i j_ = ν_0 j_ + ∑_q = 1_^Q^ ν_q j_ x_q i_ λ_i j_ = λ_0 j_ + ∑_q = 1_^Q^ λ_q j_ x_q i_ μ_i_ = α_0_ + ∑_q = 1_^Q^ α_q_ x_q i_ τ_i_ = τ_0_ exp ( ∑_q = 1_^Q^ ω_q_ x_q i_ ); For identifiability of the model it is necessary to require α_0_ = 0 and τ_0_ = 0. In case the distribution of the outcome Y_ij_ for item j is normal, the residuals variance σ_i j_^2^ is modeled by σ_i j_ = σ_0 j_ exp ( ∑_q = 1_^Q^ δ_q j_ x_q i_ ) . For ordinal outcome variables, threshold parameters are introduced. The link functions for different scales are taken as the canonical link functions.
Burns RA, Butterworth P, Kiely KM, Bielak AAM, Luszcz MA, Mitchell P, Christensen H, Von Sanden C, Anstey KJ, Multiple Imputation was an efficient method for harmonizing the Mini-Mental State Examination with missing item-level data, Journal of Clinical Epidemiology, 2011, 64, 787–793.^71^
- The proposed approach is applicable to all types of scales (continuous, count, ordinal, binary) including combinations of scales for different items in one study. However, the method does imply the assumption of missing at random (MAR), but this was only briefly mentioned in the discussion.; - The authors studied the harmonization of nine Australian longitudinal studies of aging, which all used the Mini-Mental State Examination (MMSE). MMSE is used to screen for dementia and to estimate the cognitive status of individuals. It consists of 30 items with binary outcomes (correct/incorrect) and involves items on “orientation”, “registration”, “attention”, and “calculation”.; - Each study has missing item-level data that may be associated with cognitive decline or impairment and impending mortality. Participants may fail to complete items due to other reasons (e.g., stroke, deafness, physical disability, etc.). The authors claim that mean item substitution and casewise deletion are inappropriate for handling this type of missing item-level data and they propose multiple imputation to maintain the largest possible sample of participants and the largest available amount of data.; - Percentages of missing item-level data varied strongly between studies from 0.5% to 95% participants with missing items. However, 33.8% of the participants missed just one item and only 6.8% of the participants had more than 10 items missing. For most items not more than 1% was missing but for some items as high as 15% was missing.; - Multiple imputation with chained equations (MICE), using the add-on in STATA version 10, was applied to all variables: MMSE items, age, sex, years of education, study, and study interactions. Essentially, MICE uses the conditional distribution of a variable, given all the other variables to generate new values, see Van Buuren, Brand, Groothuis-Oudshoorn, and Rubin (2006). Five imputation data sets were generated, but they only used the average value of the imputed data sets as the imputed value. Thus for the MMSE items, they imputed a probability (estimated from five imputations). Their approach seems similar to a mean substitution and therefore loses the strength of multiple imputation. They do recognize this (in their discussion), but they argue that this is more practical (and therefore appropriate). They tested the efficacy of their averaged MI approach on the complete cases, by randomly assigning MMSE items missing. Thus they only investigated their procedure by assuming that items were missing completely at random (MCAR).; - The analysis of the data demonstrated an effect of age and years of education on the missing data (by comparing the variable for participants with and without missing item-level data). Older participants and less years of education were more likely to have missing data. No items (univariate approach) seem to be related to clinical diagnosis for dementia (after correction of multiplicity), nor did clinical diagnosis for dementia affect the number of missing items for participants. The MI approach resulted in an upward shift in the mean MMSE, but a lower mean MMSE score remain true for participants with missing item-level data compared with participants with no missing item-level data after imputation. This is what the authors expected, but without arguing why this is intuitive. A priori it is not obvious that the differences should become closer.; - The efficacy study generated missing data at 5%, 10%, 15%, 25%, 50%, 75%, 90%, and 95% for a random sample of participants of size 10% and 20%. The size of participants seem without effect, but the level of missing items showed a dramatic reduction in accuracy beyond 50% of missing item-level data. The correlation between imputed and original scores drops rapidly if more missing items are missing. A t-test on the imputed values with the original values (for the 20% participants and 50% missing item-level data) was not significant. Furthermore, the use of MI elevated MMSE scores for those imputed, similar to the earlier analyses.; - The authors suggest that their MI model is correctly modifying nonresponders’ total scores, except maybe for the very old (95+). For this group less consistent results between imputed and original values were observed. They also believe that MI reflects a significant improvement to estimating total MMSE scores over previous estimation techniques. They claim that it is suitable for up to 50% missing item-level data.

2P-IRT = two-parameter logistic using item response theory; LFA = linear factor analysis; MAR = missing at random; MCAR = missing completely at random; MI = multiple imputation; MICE = multiple imputation with chained equations; MMSE = Mini Mental State Examination; MNLFA = moderated nonlinear factor analysis; UK = United Kingdom

The approach described by Gorsuch72 was not originally meant for the statistical harmonization of data, but could have some application in this context (Table 2). Gorsuch proposed extension analysis to compute the relationship among common factors to variables that were not included in the factor analysis. For example, this would be used in a situation where a factor analysis would include proven items but no new experimental items. This method, however, would still require that items could be chained together.

Most of the examples from this class of models were restricted to a single observation per individual. McArdle, et al.73 combined an item response theory approach with a latent growth/decline curve modeling to allow for repeated measures. Their method allowed for a varying number of data points per individual and for the instruments to change over time (Table 2).

The final class of methods, multiple imputation, is described by Burns, et al.71 (Table 5). In this situation, the authors were interested in combining Mini-Mental State Examination (MMSE) scores with missing data across nine Australian longitudinal studies of aging. The MMSE score comprises 11 items and the proportion of missing at least one MMSE item varied greatly by contributing study and wave of data collection. Furthermore, the missingness of information was related to demographic characteristics, especially age and education. Burns, et al. used an imputer model that utilized multiple imputation with chained equations to impute appropriate missing MMSE item scores. A detailed summary of the methods proposed by Burns, et al. is in Table 6. General issues around methods of imputation are reviewed by Peyre, et al.92 and Spratt, et al.94 (see Table 3). This method required that the same measures were included across studies, but the approach may be able to be extended to more general situations.

## Examples of Analysis of Harmonized Data

Table 4 presents a summary of 22 publications arising from 16 data harmonization projects. In many of these projects the harmonization was done in terms of standardizing response options and determining whether questions were comparable across cohorts. For example, Minicuci, et al.112 compared disability-free life expectancy using survey data collected in three populations. Data on five activities of daily living (ADL) questions that were common to all surveys were used and the response options for these questions were dichotomized to create a common scale. Pluijm, et al.113 similarly combined ADL data across six countries. There was overlap in the ADL items among the four items comprising the Katz ADL index; all four items were present in four of the six country surveys. In countries where the two items were not measured, the data for these were extrapolated from other “comparable” ADL items. Finally, subjects were excluded if two or more items were missing. Hot deck methods were used to impute values when one of the items was missing due to nonresponse.

Bath, et al.99 harmonized cognitive data from the Longitudinal Aging Study Amsterdam (LASA) and the Nottingham Longitudinal Study on Activity and Ageing (NLSAA). LASA used the Mini Mental State Exam (MMSE: 30 point scale) and the NLSAA used the Clifton Assessment Procedures for the Elderly (CAPE: 12 point scale). In the analysis, the authors simply created derived variables MMSE/30 and CAPE/12, and combined across studies.

Many of the studies used item response theory-based methods for analysis. van Buuren, et al.118 used response conversion to harmonize international disability information, while Crane, et al.102 used item response theory to co-calibrate cognitive scales. Both Curran, et al.103 and Grimm, et al.106 combined item response theory and growth curve models. Curran fit these models to data of developmental internalizing symptomology and Grimm examined the association between early behavioral and cognitive skills with later achievement. McArdle, et al.109 used linear structural equations modeling with incomplete data to analyze repeated measures twin-data to evaluate biometric genetic hypotheses in the context of intellectual growth and change. The authors incorporated a twin analysis including means and age effects, longitudinal analyses based on latent growth components, and biometric-genetic analyses for components of growth using linear structural equations models.

Schenker, et al.116 combined clinical examination data with self-reported survey data. The National Health and Nutrition Examination Survey asked self-report questions on health conditions and obtained clinical measures based on physical examinations. The National Health Interview Survey was larger and obtained a rich set of variables for use in multivariate analyses, but the study relied on self-report questions for the information on health conditions. Multiple imputation was used to properly reflect the sources of variability in subsequent analyses.

The Fibrinogen Studies Collaboration105 combined data from 31 cohort studies using a two-stage approach. In the first stage partially and, where possible, fully adjusted estimates were obtained from each study, together with their standard errors. This method addresses the issue of when studies included in an IPD meta-analysis include some, but not all, important confounding variables. This may be relevant if we have some studies fully measuring the construct and other studies only partially measuring the construct; this could be analyzed with this bivariate approach. This approach, however, does require the exposure and outcome of interest to be available across all studies. In the second stage, they combine the study-specific estimates.

## Other Related Areas of Application

In educational and achievement testing, the problems and approaches related to dealing with data collected with different instruments are discussed in terms of score linking or score equating.120 Different editions of tests are designed to measure the same constructs, but almost by definition will differ in their psychometric properties. For example, if one edition is more difficult than another, examinees would be expected to receive lower scores on the harder form. Score equating seeks to eliminate the effects on scores of these unintended differences in test form difficulty. There is a long history of research in the area of score equating which is summarized in Dorans, et al.120 Whereas the body of literature developed in the area of data harmonization in health research may be more applicable to outcomes and exposures in the majority of research studies, there are potential links in measuring constructs such as cognitive performance.

## Statistical Harmonization Methods for Application

In consultation with our TEP, three methods identified in the environmental scans were selected to create combinable cognition constructs across datasets. The methods were chosen based on their frequency of use in the literature, and their appropriateness for use with summary cognitive constructs. Methods were also selected based on the ease of application. We reasoned that if standardization methods were sufficient, one would not need to use the specialized methods that require more sophisticated statistical analyses and nonstandard software. The first two methods standardize the cognition variables to a common metric. The specific methods chosen have been used in the context of comparing or combining cognition measures in the literature. The final method chosen was a latent variable approach. This approach uses a generalized linear mixed model to identify a univariate underlying latent variable for subjects common to all datasets. The missing data-type methods were also considered but are more amenable to constructs that are collected using a large number of items across studies, most of which are overlapping, for example, measuring disability using basic and instrumental activities of daily living. As our construct of interest was an overall score we did not pursue this type of statistical harmonization. These methods are described in detail in the “Methods and Results: Implementing and Evaluating Three Methods of Statistical Harmonization Applied to Cognitive Measures (Objective 3)” section.