# Introduction

Individual Participant Data (IPD) meta-analysis has become an increasingly popular method to combine unique participant data from randomized controlled trials and observational studies.1,2 IPD meta-analyses increase the power to detect differential treatment effects across individuals in a randomized controlled trial (RCT) and allow for adjustment of confounding factors in the meta-analysis of observational studies, but they are time consuming and costly to conduct. The main advantage of IPD meta-analysis is that researchers can assess the influence of participant-level covariates on all collected outcomes and measured time points of interest, not all of which are reported in the literature.1 IPD meta-analysis is particularly relevant to comparative effectiveness reviews (CERs) when conducting sub-group analyses and when combining evidence from RCTs and observational studies examining benefits, harms, adherence, or persistence.3 However, combining individual participant data is scientifically and technically very challenging. Integration or comparison of individual participant data requires the generation of compatible (or harmonized) datasets across studies. The value of these harmonized datasets is necessarily dependent on: (1) the quality of the data collected by individual studies; (2) the potential for studies to create the variables needed to achieve statistical analysis foreseen; and (3) the acceptable level of heterogeneity across study designs and data collection methods. Such heterogeneity can result from a vast range of study-specific characteristics including, for example, the targeted population, sampling frame, tools and standard operating procedures used by the study investigators to collect data, data collection timeline, etc. To combine or compare individual participant data, it is thus important to limit integration of study-specific data to studies constructed upon clinically and methodologically compatible designs and methods. But there is no standard definition of whether studies are similar enough. The decision to combine study data to produce an overall estimate of effect depends on whether a meaningful answer to the scientific question addressed can be obtained. Harmonization is thus to be considered as a process composed of a series of complementary steps which must be applied with rigorous procedures and decisionmaking in order to ensure validity and reproducibility of the harmonization outputs.

However, in many situations a systematic review is carried out where there are multiple methods and tools used to measure the same underlying construct such as cognition or physical function. This situation is very common when one is examining the comparative effectiveness of interventions in diseases such as dementia, depression, or attention deficit hyperactivity disorder. An example that highlights these issues is in the area of vitamin D, cognition, and dementia. Balion, et al. recently conducted a systematic review that examined the association between vitamin D, cognition, and dementia.4 There have been two systematic reviews5,6 which suggest that cognitive function was not associated with 25-hyroxyvitamin D (25(OH)D). However, the authors of both reviews decided not to quantitatively pool data to come up with a summary effect because of the potential heterogeneity across studies. Their conclusions were based on whether there were statistically significant associations between 25(OH)D and one specific measure of cognition, the Mini-Mental State Examination (MMSE), although many measures of cognition were reported. Even though the authors did not pool data their qualitative interpretation of data assumed inferential equivalence of exposure and outcome measures.

Part of the difficulty in summarizing this literature is that there are potentially important methodological differences among the studies, such as the type of assay used to measure 25(OH)D, the threshold values used to define vitamin D insufficiency, and the different measures of cognition utilized. To harmonize the threshold values of vitamin D, additional summary data were requested from the authors by Balion to assess the inferential equivalence of the assay to determine whether results of different assay types could be pooled across studies.

As far as outcome measures of cognition were concerned, the challenges were much larger as the primary studies included a multitude of outcome measures that ranged from a general mental status score, such as the MMSE, to a complete neuropsychological battery. Since many studies used the MMSE, the primary meta-analysis was restricted to that subgroup of studies. A sensitivity analysis was used to examine if the relationship differed when other general cognitive measures were included. In these analyses, a difference in the relationship between 25(OH)D and MMSE based on the type of assay used was found; a consistency was found when the analysis focused exclusively on MMSE and when all general measures of cognition were included. In one analysis, potential methodological differences among the studies were examined, and in the second analysis, Balion, et al. assessed if the same construct was measured. To do this, it was assumed that MMSE measured the same general cognition construct among the studies and that other similar tools measured the same construct. When one is restricted to traditional aggregate data (AD) meta-analysis one is limited to subgroup and sensitivity analyses to examine whether the variables are inferentially equivalent across studies. When one has access to IPD, however, a more complex analysis can be undertaken to assess the inferential equivalence before data are pooled or to have the ability to create new inferentially equivalent variables that allow unbiased pooling of the data.

In the current report, we consider, in the context of the harmonization process, two different data processing methods: (1) qualitative harmonization and (2) statistical harmonization. The choice of which method to employ depends on the nature of the measure to be harmonized. On the one hand, the generation of compatible or inferentially equivalent information across studies can involve creating simple study-specific cut-points for a variable like age or troponin I level or combining different response categories across studies to make them compatible. This is what we refer to as qualitative harmonization and is done using processing algorithms that derive data collected by different studies into a common format. Combining data on more complex constructs such as cognition, physical function, depression, or anxiety can be particularly challenging. To harmonize such constructs, it is essential to use specialized methods such as statistical harmonization or processing. With this second method, statistical models are applied to derive common format data. With both methods, a rigorous step by step approach to harmonization will ensure reproducibility of the harmonized databases and greatly increase the quality and precision. The application of such methods of harmonization in the conduct of systematic reviews is virtually nonexistent.

Although statistical methods for harmonization have been proposed, there has not been a comparative assessment of the strengths and weaknesses of these specialized methods as it relates to the conduct of systematic reviews. Such an assessment could help users identify the most appropriate method given a specific context. For this report, an environmental scan was performed on the methods used to combine different complex measures across studies, and then a few of these methods were applied to create combinable derived variables using three large population-based cohort studies. While a rigorous generic harmonization and decisionmaking process was used to select studies and combine data, the present report focuses on the usage of specialized statistical harmonization.

IPD analysis is an area of interest for the Agency for Healthcare Research and Quality (AHRQ), but there are currently no guidelines for its use.7 A conceptual background on the need for harmonization and methods used to harmonize information across studies, as well as a background on the different types of cognitive measures that are used in CERs is provided.

## Data Harmonization

Ensuring data compatibility and inferential equivalence through harmonization allows integrating information from different studies/databases and can thereby permit pooling of data from a large number of studies to obtain statistically valid results. It also allows one to properly explore the similarities and discrepancies across studies, jurisdictions, or countries, and improve the validity and reliability of comparative effectiveness research.

IPD harmonization essentially aims to attain, or improve, compatibility of information collected from similar but independent sources.8 This can be achieved by making use of different approaches.9 If we consider when the harmonization process takes place in the lifecycle of studies, we can distinguish between prospective and retrospective harmonization approaches. Under prospective harmonization, study investigators will agree upon common measures and protocols before beginning data collection. Agreement on a core set of common measures and collection procedures prior to data collection will facilitate future integration or comparison of data across standalone studies. However, IPD meta-analysis in comparative effectiveness literature is generally achieved by making use of retrospective harmonization. Retrospective harmonization takes place after collection of study-specific data has been initiated, generally without any attempt to prospectively ensure a certain level of compatibility across studies. This retrospective approach thus necessitates a rigorous documentation of studies participating in the exercise and a meticulous process to harmonize and integrate study-specific data under a common format. Under both prospective and retrospective harmonization, the ultimate potential to integrate information is directly related to the level of heterogeneity amongst study-specific populations, designs, and standard operating procedures used by study investigators to collect data. An explicit harmonization process is generally not undertaken by the systematic reviewers. When combining IPD to achieve meta-analysis, it is thus essential to interpret whether individual variables and measures are similar, both qualitatively and quantitatively. Thus, prior to analysis a process of data harmonization is required.

To achieve IPD harmonization, investigators of any retrospective harmonization initiative will need to follow a series of practical steps. Firstly, once a research question guiding the harmonization initiative has been identified, investigators identify and document the characteristics of participating studies, such as study designs and data access and usage policies, and all relevant information describing samples, data items, and collection methods, such as data dictionaries or codebooks, questionnaires, and standard operating procedures. This documentation allows the identification of sources of study heterogeneity and provides the elements required to achieve proper evaluation of the harmonization potential across studies. Secondly, based on documentation obtained and the scientific aims of the harmonization initiative, variables targeted to serve as reference for data harmonization across studies are selected. A priori selection of variables targeted for harmonization is generally guided by a balance between enabling integration of a significant number of studies to provide the benefits of large sample sizes, while restricting integration to studies providing the lowest level of heterogeneity possible. Finally, following the identification of reference variables and the selection of studies collecting the valid information required to construct these variables, various methodologies can be applied to transform study-specific data items under the target variable format. As we have seen, these include both qualitative harmonization and statistical harmonization methodologies. Qualitative harmonization involves processing study-specific data items using logical algorithms, and is often applied to create dichotomous or categorical variables (e.g., ethnic background, type of cancer, or smoking status). In addition to qualitative harmonization methods, statistical harmonization methods may be used to harmonize complex constructs, such as cognition, and also requires processing study-specific data items to create an inferentially equivalent construct before data pooling can begin. The choice of which harmonization method to use therefore depends on the nature of the measures to be harmonized.

In addition to providing key scientific benefits and increasing potential for cross-national and international collaborations, IPD harmonization enables and encourages secondary use of existing and emerging research infrastructures. There is without any doubt a growing interest from researchers and funding agencies for the development of more efficient IPD harmonization methodologies and resources. These methodologies will be essential to improve the quality and research potential of current IPD harmonization capacities, and therefore support the achievement of the next generation of specialized international research initiatives.

## Harmonization of Data on Cognitive Functioning

In the context of comparative effectiveness reviews and technology assessment reviews, one is almost by definition undertaking a retrospective harmonization. When examining pharmacological treatment of dementia, for example, Raina et al. examined three broad categories of pharmacologic treatments: (1) cholinergic neurotransmitter modifying agents, (2) noncholinergic neurotransmitter/neuropeptide modifying agents, and (3) other pharmacological agents.10 As many studies used a wide variety of cognitive function measures as outcomes, the authors had to determine which measures could be statistically combined without any methodological guidance. In this report 20 different “general” scales were identified and only the most commonly reported MMSE11 and the Alzheimer’s Disease Assessment Scale,12 were included in quantitative meta-analyses, therefore resulting in a loss of information.

A major step in combining or comparing results across studies involves identifying comparable variables and assessing the potential for harmonizing the data. The similarity of a measure can vary at a number of levels, and even when using the same measure, large operational differences can be found.13 When considering combining data sets from across the world, these differences can be magnified. Regardless of whether the same measure has been used, differences are inevitably introduced due to language, administration, and item relevance. Furthermore, sampling characteristics can be strikingly different such that results from different studies may reflect different sections of the population. A balance must be found between optimal similarity of administration, similarity of meaning, and significance of meaning thereby avoiding unreasonable loss of information or lack of depth. The process of retrospective harmonization is essential. Systematic reviewers must take these issues into account prior to deriving common variables that can be combined to create an overall estimate of effect of a given intervention or exposure.

### Types of Cognitive Measures

Cognitive ability measures can be classified into different structures. The most psychometrically validated structure is the Cattell-Horn-Carroll theory which identifies 10 broad stratum abilities comprising over 70 narrow abilities.14 A variety of tasks are also used to measure the construct of executive functioning, considered to be a complex function of multiple cognitive processes involving planning, attention, working memory, verbal fluency, inhibition, flexibility, initiation, and monitoring of actions. Many of the measures of the cognition reported in primary studies assess somewhat different underlying constructs, and therefore create a substantial challenge for systematic reviewers.

Some of the most common measures are the following:

#### Memory

Short-term memory is the ability to apprehend and retrieve elements within a few seconds. Long-term storage and retrieval memory is the ability to store and retrieve information over longer term periods. Although many of the studies use standard measures such as the Wechsler Adult Intelligence Scale (WAIS) Digit Span subtests,15 the Wechsler Memory Scale Logical Memory Test,15 or the memory items from the MMSE,11 a large majority of the immediate and delayed word list recall tests are based on different words and different numbers of stimuli and exposures.

#### General Mental Status Exams

The primary purpose of mental status exams is as a screening measure for identifying individuals with cognitive impairment. Such exams, therefore, contain items focused at the lower end of cognitive function with maximum scores typically obtained by nonimpaired adults (producing ceiling effects). The MMSE11 is a commonly used scale in longitudinal studies and clinical trials. Because it is a screening device, this measure will not provide good specificity compared with other cognitive assessments.16 Mental status exams are commonly used in medical and epidemiological studies that might not have obtained other cognitive measures. MMSE-based tests have been developed with a higher range of measurement (e.g., the Cambridge Cognition Examination17 and the Modified Mini-Mental State Exam [3MS]18).

#### Verbal/Crystallized Knowledge

Many longitudinal studies use at least one of the WAIS Revised,19 including Vocabulary, Synonyms, and Similarities. However, a number of studies have made use of idiosyncratic or short forms (e.g., three item subsets) of these scales. The National Adult Reading Test20 and the Mill Hill Vocabulary Scale21 are also markers of this cognitive ability.

#### Fluid Reasoning

This ability includes measures of the ability to reason, form concepts, and solve novel problems. Measures of fluid ability include the WAIS Block Design subtest, Cattell Culture Fair Test,22 the Raven Progressive Matrices,21,23 and WAIS Figure Logic.15 Other matrices and rotation tests such as Thurstone Primary Mental Abilities Spatial Orientation and Card Rotations24 are also used in a variety of longitudinal studies.

#### Speed

A variety of rapid scanning or cognitively simple tasks are used to measure the reaction time or speed of response. Substitution coding modalities (e.g., WAIS Digit Symbol, Symbol–Digit, Symbol–Letter),15 alphabet coding, and simple/complex reaction time measures dominate the speed domain.

#### Working Memory/Attention

Working memory involves the manipulation of information that is held in temporary storage and is a fundamental process involved in many other cognitive tasks. WAIS Digit Span Backward and Serial 7’s from the MMSE are the most common measures that can be considered to measure working memory.

#### Verbal Fluency

Verbal fluency tasks tap a complex set of cognitive functions and do not fit clearly into either verbal ability or memory constructs. Verbal fluency is measured mainly by category word fluency (e.g., animals) and first letter (e.g., FAS) word fluency tasks that require individuals to generate as many words as they can within a specified time limit. Word fluency has also been used as a measure of executive function.

### Potential Methods for Harmonization of Cognitive Variables

The type of response of a participant to an item depends on how the item is formulated. In the simplest form the response of a participant to an item is considered either correct or wrong (i.e., dichotomous), while the most informative setting would provide a continuous response to an item (i.e., numerical value). For this latter setting factor models or analysis would be used to analyze this type of data while for the former setting item response theory (including the well-known Rasch model) is typically applied. Note that item response theory has been extended to polytomous items (a categorical outcome with more than two outcomes) as well.

#### Factor Models

Factorial invariance and the larger enterprise of measurement are foundational aspects of empirical research.25,26 This is especially true where important objects of study are latent constructs whose nature and validity are simultaneously derived from consideration of a set of interrelationships with other latent and observed constructs. The establishment of measurement equivalence is essential for studies that implicitly require the quantitative comparability of constructs across samples differing in birth cohort, country, culture, and over time.

#### Factorial Invariance

Any study with the aim of making comparisons across time or groups assumes measurement equivalence, but it is possible to test this assertion using factorial invariance. A logical hierarchy of constraints in factor models begins with configural invariance,27 requiring that the same number of factors and pattern of salient factor loadings be equivalent across groups. It is identified by fixing the factor estimate (i.e., mean, variance) in one group and propagating the identification by constraining the corresponding parameter (i.e., intercept, loading) of a reference indicator across groups. Using this as a baseline, Meredith’s hierarchy of constraints25,26,28 is fit to the data: (1) weak factorial invariance, or “metric” invariance, involves equivalence of factor-variable regressions (i.e., factor loadings); (2) strong factorial invariance adds constraints on manifest intercept (mean) terms and requires that one factor mean be fixed to specify the metric of the latent variables; and (3) strict factorial invariance further constrains unique variances to be equivalent. Apart from the identifying constraints, factor variances, covariances, and factor means must be freely estimated, as factorial invariance concerns only the measurement model. A sequence of nested models from least to most constrained is recommended. For multi-occasion models in the context of considerable age-based change, bias may result unless age heterogeneity is small, compared with the amount of change expected.26,29 In such cases, chronological age differences will be controlled statistically for evaluating factorial invariance.

Factor models with polytomous (ordered categorical) indicators and robust procedures for item-level invariance tests are important extensions of factorial invariance testing procedures. Recent software enhancements relax the assumption of continuous and normally distributed indicators and permit direct analysis of binary and ordinal (polytomous) indicators. Although we will make use of factor-based models for test of factorial invariance, we note its equivalence to the graded response model within item response theory.30,31 Recent developments also permit direct estimation of categorical factor models with incomplete data.

#### Item Response Models

Item response theory provides a formal model of the individual’s response to items comprising a scale. It offers many advantages in the development and refinement of psychometric instruments. One major benefit of an item response theory framework is that the placement of items onto a continuum of difficulty (severity) facilitates comparably scaled construct scores from two measures with overlapping but disjointed item sets. While evidence of cross-cultural or cross-age factorial invariance validates the comparability of construct scores across studies, factorial invariance procedures are silent regarding options when invariance is not demonstrated for some items. Factor models (i.e., item loadings) are estimated in the context of the other items and factors in the measurement model. It is problematic that the same item may have different loadings as the context changes with the addition or removal of specific items or other factors from the measurement model. Although an item’s item response theory difficulty and threshold parameters are estimated in the context of a sufficiently large item pool, and this is analogous to the context of factor-analytic models, obtaining comparable scores from disjoint item sets is much more straightforward in an item response theory framework, and will be an important tool for data harmonization.

There is a close relationship between item response theory and certain classes of factor models.31,32 Further synthesis of item response theory and factor-analytic measurement models is an important aspect of this data harmonization methodology. Factor-analytic models are preferable when constructs are multidimensional (e.g., somatic, cognitive, emotion dimensions of depression) and items are factorially complex, which is often the case. Factor models also readily extend to first and second order latent constructs, whereas item response theory models focus on first order unidimensional latent constructs, estimating the measurement parameters of an item in the context of one such construct at a time.

#### Latent Variable Models

Factor analysis and item response theory are considered latent variable models within the field of statistics and the latent variable models themselves form a special class within the larger set of linear and generalized linear mixed models.33–35 Some measures, such as memory, working memory, and word fluency are not represented by a continuous response nor by a dichotomous or polytomous response. They represent some kind of summary score or overall test score that is based on a count of the number of items tested with specific properties (e.g. the correct recall of specific words tested). These overall test scores should therefore not be analyzed with factor analysis or item response theory.

The individual items for the memory tests could in principle be analyzed with item response theory, if the responses of these items would be available for participants, but such models would not provide direct relationships between the overall test score and the memory construct. The overall test score can also be analyzed with a latent variable model using, for instance, a binomial distribution to be able to represent counts. In these latent variable models it can also be assumed that the ability of the participant would determine the probability of an outcome of a response in combination with the specific parameters for the memory tests, similar to factor analysis and item response theory.

The ability of a participant would be represented by a single or unideminsional latent variable and it would naturally vary with participants, forming some kind of population distribution for the construct of interest of the participants. This distribution could be represented by a normal distribution (which is also typical in factor analysis and item response theory) or by any other alternative distribution such as a log normal distribution. The probability of an outcome of the memory test could be taken equal to a binomial distribution (as just mentioned) with a logit link function to connect the specific parameters of the memory test together with the latent variable to the probability parameter of the binomial distribution. The number of specific parameters for the memory test that can be used in the data analysis may depend on how many memory tests (or overall test scores) would actually be used on the participants to measure the construct memory. Two types of parameters, that may have similar interpretations as the parameters in the two-parameter item response theory, could be essential. One type of parameter would indicate how difficult it would be to correctly respond to the memory tests. This parameter would relate to the origin or location of the latent variable. A second parameter would indicate the discrimination of the memory test, because some memory tests may discriminate between participants better than other memory tests. This parameter would then relate to the variability of the latent variable.

## Primary Objectives

The primary objectives of this project are: (1) to conduct environmental scans to identify approaches to statistical harmonization which could be used in the context of aggregate data and/or individual participant data meta-analysis of cognitive measures; (2) to conduct retrospective qualitative harmonization of available data sets to prepare them for statistics harmonization; and (3) to evaluate different approaches to statistical harmonization when applied to cognitive measures.