# Glossary of Statistical Terms

Attenuation: where observations on bivariate material are subject to errors of measurement the true correlation between the variates will be obscured, usually being underestimated. The correlation is then said to be attenuated.
Binomial distribution: is the discrete probability distribution of the number of successes in a sequence of n independent yes/no experiments, each of which yields success with probability p.
Cocalibrate: consists of the simultaneous analysis of the responses of persons in a single sample to items in more than 2 instruments.
Cohen’s d: Cohen’s d is defined as the difference between two means divided by a standard deviation for the data.
Configural invariance: configural invariance is achieved if the model of interest fits across the groups. Although the model is the same across groups, the unknown parameters of the model are assumed to be different across the groups.
Confounding factors: in studies there are often unsuspected systematic differences in the way groups were treated in addition to the intended treatment conditions. Statisticians describe systematic differences of this sort as confounding factors or confounding variables.
Continuous variable: a variable that can take on any number of possible values. Practically speaking, when a variable can take on at least 10 values, it can be treated as a continuous variable. For example, it can be plotted on a scatterplot and certain meaningful calculations can be made using the variable.
Convergence: this describes whether the maximum-likehood algorithm has converged or not.
Covariates: variables not controlled for in the experiment that still affect the dependent variable.
C-score: C-scores are similar to ratios in that they both are measures of relative size. C-scores are calculated as the difference between the Z-score of a single measurement for a given individual and the mean Z-score of that individual for all the measurements used in the analysis.
Differential treatment effects: are indicated by the regression lines of the group crossing and having opposite signs. If only one of these criteria is met only a partially differential effect can be assumed.
Dummy variables: a dummy variable (also known as an indicator variable) is one that takes the values 0 or 1 to indicate the absence or presence of some categorical effect that may be expected to shift the outcome.
Extension analysis: determining the relationship of common factors to variables that were not included in the factor analysis.
Factorial invariance: factorial invariance is present if item responses are associated with the same constructs and if the factor parameter estimates are not significantly different.
Generalized linear mixed model: a model for linear and nonlinear effects of continuous and categorical predictor variables on a discrete or continuous but not necessarily normally distributed dependent (outcome) variable.
Goodness of fit: assessment of the agreement of the data with either a hypothesized pattern (e.g., independence of row and column factors in a contengency table or the form of a regression relationship) or a hypothesized distribution (e.g., comparing a histogram with expected frequencies from the normal distribution).
Harmonization: procedures aimed at achieving and improving the comparability of different surveys.
Heterogeneity: in meta-analysis refers to the variation in study outcomes between studies.
Inferential equivalence: the potential for harmonization of selected information from individual studies.
Item Response Theory: provides a model-based linkage between item responses and the latent characteristics measured by a test of scale.
Latent variable: a variable which is unobservable but is supposed to enter into the structure of a system under study, such as demand in economics or the “general” factor in psychology. Unobservable quantities such as errors are not usually described as latent.
Least square means: a method of fitting a straight line or curve based on minimization of the sum of squared differences (residuals) between the predicted and the observed points.
Linear structural equations modeling: a statistical technique for testing and estimating causal relations using a combination of statistical data and qualitative causal assumptions.
Likelihood ratio test: a general purpose test of hypothesis Ho against an alternative H1 based on the ratio of two likelihood functions, one derived from each of Ho and H1. The statistics l is given by l = -2 ln (LH0 / LH1) and? has approximately a C2 distribution with df equal to the difference in the number of parameters in the two hypotheses.
Linear or z-tranformations: a change to a variable characterized by one or more of the following operations: adding a constant to the variable, subtracting a constant from the variable, multiplying the variable by a constant, and/or dividing the variable by a constant.
Measurement invariance: attempts to verify that the factors are measuring the same underlying latent construct within each group.
Meta-regression: an extension to subgroup analyses that allows the effect of continuous, as well as categorical, characteristics to be investigated, and allows the effects of multiple factors to be investigated simultaneously.
Multiple imputation: missing values for any variable are predicted using existing values from other variables. The predicted values, called “imputes”, are substituted for the missing values, resulting in a full data set called an “imputed data set.”
Nonlinear factor analysis: maximizes shared information among nonoverlapping sources, producing higher-order features of the data which uncover hidden causal factors controlling the observed phenomena.
Point estimate: endeavours to give the best single estimated value of a parameter, as compared with interval estimation, which proceeds by specifying a range of values. Since the point estimate is surrounded by a band of error, the distinction between two methods is sometimes blurred and in interpretation they often amount to the same thing.
Polytomous Rasch model: a generalization of the dichotomous model which can be applied in contexts in which successive integer scores represent categories of increasing level or magnitude of a latent trait, such as increasing ability, motor function, endorsement of a statement, etc.
Repeated measures: in this design, the same experimental unit is subjected to the different treatments under consideration at different points in time. Each unit, therefore, serves as a block. If for example, two different treatments and placebo treatment are applied to the same patient sequentially, this is a repeated measures design.
Sensitivity analysis: a “what-if” type of analysis to determine the sensitivity of the outcomes to changes in parameters. If a small change in a parameter results in relatively large changes in the outcomes, the outcomes are said to be sensitive to that parameter.
Stratum: when data are stratified according to its characteristics, each subgroup is a stratum.
T-score: a ratio of the departure of an estimated parameter from its notional value and its standard error.
Z-score: the Z score or value expresses the number of standard errors by which a sample mean lies above or below the true population mean. The Z-statistic is defined as difference of sample proportions divided by standard error of difference of sample proportions.