# Technical Expert Panel

- Steph van Buuren, Ph.D.
  Professor, Social and Behavioural Sciences
  University of Utrecht
  Utrecht, the Netherlands
- Joseph Beyene, Ph.D.
  Associate Professor, Dept. of Clinical Epidemiology & Biostatistics
  McMaster University Chairholder: John D. Cameron Endowed Chair in Genetic Epidemiology
  McMaster University
  Hamilton, Ontario, Canada
- Vincent Ferretti, Ph.D.
  Principal Investigator and Senior Scientist, Informatics and Bio-computing Platform
  Ontario Institute of Cancer Research
  Toronto, Ontario, Canada
- John Gallacher, Ph.D.
  Reader in Environmental Epidemiology and Director of the Active Age Research Group
  Cardiff University
  Cardiff, United Kingdom
- Peter Granda, Ph.D.
  Assistant Director, General Archive Manager, International Archive of Education Data
  University of Michigan (Inter-University Consortium for Political and Social Research)
  Ann Arbor, MI
- George Kelley, DA, FACSM
  Professor and Director, Meta-Analytic Research Group
  Department of Community Medicine
  West Virginia University
  Morgantown, WV
- Julian Little, Ph.D.
  Professor and Chair, Epidemiology & Community Medicine
  Canada Research Chair in Human Genome Epidemiology
  University of Ottawa
  Ottawa, Ontario, Canada
- Jack McArdle, Ph.D.
  Professor of Psychology and Gerontology
  Director of the National Growth and Change Study
  University of Southern California
  Los Angeles, CA