# Key Informants

- Steph van Buuren, Ph.D.
  Professor, Social and Behavioural Sciences
  University of Utrecht
  Utrecht, the Netherlands
- Andrea Piccinin, Ph.D.
  Associate Professor, Dept. of Psychology
  University of Victoria
  Victoria, British Columbia, Canada
- Christopher Schmid, Ph.D.
  Associate Professor of Medicine at Tufts University School of Medicine
  Concentration Leader for the Clinical Research Program
  Sackler School of Graduate Biomedical Sciences
  Boston, MA
- Ronald Stolk, Ph.D.
  Professor and Department Head, Clinical Epidemiology
  University of Groningen
  Groningen, the Netherlands