# Acknowledgments

The researchers at the McMaster EPC would like to acknowledge the following people for their contributions. We are grateful to our Task Order Officer, Parivash Nourjah, for her support and guidance. Members of the Technical Expert Panel were instrumental in the formation of the parameters and goals of this review. We would like to thank the staff of the Maelstrom Research Program, specifically Dany Doiron, for their contributions to the review. We would also like to thank those who worked so conscientiously, retrieving and screening citations, abstracting data, preparing figures, and editing the report: Julianna Beckett, Bryan Cheeseman, Roxanne Cheeseman, Mary Gauld, Meghan Kenny, Leah Macdonald, and Maureen Rice.