# Discussion

To address our overall objectives, this report comprises two environmental scans of the literature on statistical harmonization methods and an application of three methods of statistical harmonization to cognition data from three population-based cohort studies. This application was designed to examine the properties of these different methods of statistical harmonization and how the choice of method impacts meta-analysis results.

## Environmental Scans

Summary and detailed information extracted from the articles that were selected from our environmental scan are provided in Tables 1 through 6. They contain articles on meta-analysis of cognitive measures, on statistical harmonization, and on studies of harmonized data. The environmental scan of meta-analyses including cognitive measures revealed that all summary data meta-analyses including cognition outcomes either restricted their analyses to a subset of studies for which cognitive measures with a common scale were used or combined effect sizes across studies. None of the studies formally explored if the cognitive measures should be harmonized.

In our environmental scan of the methods of statistical harmonization we found three general classes of methods. The first class uses a simple linear- or z-transformation to standardize the scale of constructs across datasets. The second class of methods posits that there is a latent factor(s) that underlies a set of measured items that can be modeled, while the third class of methods was an “incomplete data” approach in which multiple imputation procedures or maximum likelihood estimation could be used to impute values for missing items. These items are then used to calculate a common scale that could be combined across studies. Each method has strengths and weaknesses and all require at least some overlap in items or scales among studies to be able to harmonize the data. In the literature scan no examples were found where methods other than creating an effect size or a standardized score were used to combine cognitive scores in an aggregate data meta-analysis.

In general, there was little focus in the literature on methods used to determine the inferential equivalence of variables prior to statistical harmonization. This “pre-statistical” harmonization step may have, in fact, been conducted, but was not often reported. Granda, et al.69 describe general approaches to harmonization. The authors describe issues around determining cultural equivalence as a component of inferential equivalence. For example, Pluijm, et al.113 describe harmonizing measures of activities of daily living in older people across six countries. For some specific activities, questions used to collect data were similar, but there were cultural differences in meaning attached to the performance of the activities. For example, in Southern European countries, older people receive help for cutting their toenails even if they do not have any difficulty in completing the task. The implication is that even when variables are standardized by such efforts as the Core Outcome Measures in Effectiveness Trials (COMET) Initiative,169 careful pre-statistical harmonization is required.9

Data from three Canadian population-based studies were compared for this report. There were methodological and design differences among the studies. For example, Canadian Community Health Survey on Healthy Aging (CCHS) recruited community-dwelling participants, while Canadian Study on Health and Aging (CSHA) included both community-dwelling participants and institutionalized participants, and the Quebec Longitudinal Study on Nutrition and Aging (NuAge) included participants who, at baseline, did not have serious chronic conditions. As well, although the data did not arise from different countries, there was the potential that language differences across the study populations could have an impact on the cognitive tests. The NuAge cognitive battery was administered only in French, while the CSHA and CCHS participants could choose to have the cognitive modules in French or English. In the CSHA, Steenhuis and Østbye found that, particularly on language-based cognitive tests, persons tested in French tended to have lower scores than persons tested in English.170 If this was an indication that the underlying construct being measured by the French and English versions of the test differed, this could impact the decision to create a single latent variable or even to combine these studies. Since part of our interest was to see whether the different methods of statistical harmonization were able to identify “important” heterogeneity, we combined these data. It was of interest, however, that although adjustment for covariates slightly attenuated the mean cognitive scores within the studies, it had little impact on the qualitative conclusions of the meta-analyses.

The item response theory methods from the environmental scan also focused on harmonizing data when a number of individual items are available for each study, with some overlap of items between studies. We chose to use summary measures instead of individual items of the tests in this report as these best represent the type of data one would be including in a comparative effectiveness review (CER). This choice required us to have more than one summary variable per study to attain model convergence. Note that in item response theory models three items are required to be able to estimate the latent trait properly. Therefore, in CCHS-Canadian Longitudinal Study on Aging (CLSA) we included an additional memory subscale, the Health Utilities Index (HUI^®^). In our latent variable analysis it was assumed that the overall test scores of a subject were influenced by a univariate continuous latent variable and the overall test scores are viewed as counts representing a correct number of scored test items. The HUI, however, is slightly different in that it is not a count but an ordinal scale. It was interesting that although the results indicated that the T-score for the HUI had a completely different relationship with the latent variable, the relationship between the Rey from CCHS-CLSA (after including the HUI in the latent variable model) and CSHA with their comparable T-scores, was similar. It should be noted, however, that the quadratic relationship between the T-score and the latent variable model was still more similar for the Buschke tests between the CSHA and NuAge than the relationship between the Rey tests between the CSHA and CCHS-CLSA.

## Comparison of Statistical Harmonization Methods

Analyses included three methods of statistical harmonization identified from the environmental scan. Two methods standardized the cognition variables to a common metric. The final method used a generalized linear mixed model to identify a univariate underlying latent variable for subjects that would measure the construct common to all studies. Information on the latent variable model was presented in Table 13 and comparisons between the different choices of outcome measures (T-scores, C-scores, latent variable) are provided in Tables 15 and 17.

We did not explore the missing data-type methods as they are more amenable to constructs that are collected using a large number of items across studies, most of which are overlapping. As our construct of interest was an overall score we did not pursue this type of statistical harmonization. It should be noted, though, that the latent variable model is estimable with incomplete data, when item or scale pairing has been observed in at least one study, and can be used to predict missing items.

In our aggregate data meta-analyses that were reported in tables 18 through 20, we found some difference based on the method of harmonization. In terms of the magnitude of effect in the unadjusted analyses, the Hedges’ g based on the raw data and the C-scores were most similar. The T-score effect sizes tended to be somewhat attenuated, but this is due to the inherent adjustment for age, sex, and education level of the T-scores. Adjustment for a common set of covariates attenuated the effect sizes for all methods, but there were no systematic differences in the magnitude of the effect sizes across the methods of harmonization.

Because of the methodological differences among the studies it was anticipated that residual heterogeneity would exist that would not be accounted for by the variables included in the analyses. It was also hypothesized that the Rey and the Buschke Free would be most similar as they both are measures of free recall. If heterogeneity did exist, it would be most evident when the Buschke Total and the HUI were being combined with the Rey and Buschke Free. In most cases there was a clear indication of heterogeneity. Using a criterion of P_Q_<0.05, 99/120 (83 percent) of the analyses indicated there was statistically significant heterogeneity. Although, 5 of the 21 cases in which heterogeneity was not indicated combined the Rey and Buschke Free only, this was not consistent with a prior hypothesis that these cognitive measures would be most similar.

When heterogeneity was not found at the P_Q_<0.05 level, 14/23 (61 percent) of the analyses involved the T-Score. When a more conservative level of P_Q_<0.10 was used, all four analyses in which heterogeneity was not indicated using the P_Q_<0.10 criterion involved a T-score. As the T-score is adjusted for age, sex, and education, it may tend to make the study-specific measures more similar. The other analyses indicating a lack of heterogeneity included adjusted estimates; however the only analysis with an I^2^ <0.5 included T-scores. The relative inability to detect heterogeneity when using the T-score standardization makes it a less desirable method of statistical harmonization.

The latent variable analyses were able to further explore these relationships. The effect of sex, age, and education on the latent variable was different across studies. Both the mean and the standard deviation of the latent variable were different, which indicates clear heterogeneity across studies. This heterogeneity was demonstrated in most, but not all, meta-analyses. Furthermore, evidence was found that the Rey was significantly more difficult than the Buschke Free recall in CSHA but, as expected, it was also demonstrated that the Buschke Total recall is substantially easier than the Buschke Free recall in the CSHA and NuAge. This may suggest consistency in the Buschke test across the studies, which would be one form of measurement invariance.70 Unfortunately, there was a significant lack of homogeneity for Buschke tests across the CSHA and NuAge, which means that there was no measurement invariance for the Buschke tests. This type of analysis which informs the potential combinability of constructs, however, is not possible without at least some individual-level data.

The ability to detect heterogeneity was used as a criterion in assessing the desirability of statistical methods of harmonization in summary data meta-analysis. When undertaking such an analysis, the underlying assumption is that the construct being measured is the same across measures and datasets. Usually in a meta-analysis, one does not have access to the individual participant data that allows the exploration of this assumption. If the assumption was valid, and there was no bias introduced by using more straightforward methods of statistical harmonization, such as standardization, would be the most desirable method as it is easily implemented and can be computed using standard software. The criterion to measure the appropriateness of a statistical harmonization method, therefore, may differ by context.

## Issues in Applying Statistical Harmonization Methods

Data from observational studies are presented in this report; methods to retrospectively harmonize outcome, exposure, and covariate data were used. If one were applying harmonization methods to a meta-analysis of RCTs, using unadjusted measures of effect is generally more appropriate, and thus the inclusion of covariate data would not be warranted. There are situations, however, when one is interested in effect modification in which combinable covariate data are required. As well, in the context of evaluating harms, one is often limited to nonexperimental data. In such a case, both qualitative harmonization (the processing of study-specific data items using logical algorithms, often applied to create dichotomous or categorical variables) and statistical harmonization may be required.

Any study making comparisons across time or groups assumes measurement invariance. It is possible to test this assertion using factorial invariance when some items are measured across studies. A logical hierarchy of constraints in factor models begins with configural invariance,27 requiring that the same number of factors and pattern of salient factor loadings be equivalent across groups. It is identified by fixing the factor estimate (i.e., mean, variance) in one group and propagating the identification by constraining the corresponding parameter (i.e., intercept, loading) of a reference indicator across groups. Using this as a baseline, Meredith’s25 hierarchy of constraints26,28 is fit to the data: (1) weak factorial invariance (also known as “metric” invariance) involves equivalence of factor-variable regressions (i.e., factor loadings); (2) strong factorial invariance adds constraints on manifest intercept (mean) terms and requires that one factor mean be fixed to specify the metric of the latent variables; and (3) strict factorial invariance further constrains unique variances to be equivalent. Factor variances, covariances, and nonreference factor means must be freely estimated, as factorial invariance concerns only the measurement model and not the structural model. A sequence of nested models from least to most constrained is recommended. Factorial invariance was not evaluated here, given the limited number of tests available across these three studies, but heterogeneity of the Buschke test across studies was observed.

### Issues in Applying Statistical Harmonization to Other Types of Data

In this project we included only cross-sectional data. This issue of invariance is further complicated when one considers repeated measures of constructs over time. In our environmental scan, we found that some methods were limited to one observation per participant. For example, the method of Bauer, et al.70 required independent observations. Other authors used growth curve models to accommodate repeated observations.73,103,106 Regardless of the method, careful consideration needs to be taken to assure the invariance in a construct over time. When studies use different measures and different followup schedules, the potential for assessing longitudinal invariance across studies may be confounded by differences in measurement and potential differences in the detected pace of natural development. An example of a related issue is practice effects for repeated cognitive measures over time171 Essentially, on repeat testing, improvement can occur because of an intervention or natural recovery but also because of gains related to prior exposure to the testing materials. The practice effect, a complex process related to decreased anxiety, familiarity with the testing situation, and gains due to strategy and content familiarization, is usually not uniform across measures172 and can be associated with other factors such as age or initial ability level.173 As well, some researchers try to diminish practice effects by using alternate forms in serial neuropsychological testing,174 but this often leads to additional difficulties due to nonequivalent forms. In addition, for multi-occasion models in the context of considerable age-based change, bias may result unless age heterogeneity is small compared with the amount of change expected.26,29 In such cases, chronological age differences must be adjusted statistically when evaluating factorial invariance or analyses can be performed in age-homogenous subsamples. If heterogeneity across studies completely explains the differences in the latent variable only, differences in tests would be consistent across studies. All of these factors contribute to the complexity of the harmonization exercise.

Although we focused on cognitive measures in this project, our results are relevant to combining any complex construct. The same harmonization issues are relevant when considering outcome measures such as physical functioning,13,113 quality of life,171,175 or exposures such as nutritional intake.101,176 Whereas repeated measures of these constructs may not be associated with “practice” effects, similar issues will arise when instruments are culturally interpreted among clinical sites or adapted over time.

### Alternative Statistical Methods for Harmonization

Latent variable models as a class of statistical models, which include factor analysis, item response theory, and the current latent variable model for count data, is a very general and appropriate class of models for harmonization of psychological measurements. They transform the test results into a continuous measurement of the latent trait that is believed to be underneath the test measures. Our example demonstrated this using the different memory tests. The latent variable models could handle continuous, counts, ordinal, and binary outcomes, although combinations of these types of outcomes would most likely require substantial programming in a sophisticated software package. Truncated continuous variables can also be handled with latent variable models, since this would lead to some form of the Tobit model. The latent variable models would typically implement a single one-dimensional trait, but there is essentially no restriction to use unidimensional traits. This means that multidimensional traits can be implemented as well and these types of models would become similar to structural equation models. Although latent variable models are very general, they do not contain Bayesian methods or multiple imputation methods. These latter two have not been explored in our study but may provide alternative approaches for harmonization.

For instance, Bayesian methods for item response theory have been developed by Fox and Glas.177 It is argued that Bayesian methods for item response theory are more flexible than the maximum likelihood approach, which is typically the method of estimation for latent variable models, since Bayesian approaches could handle more complicated data such as complex hierarchical structures. Bayesian methods would use Markov Chain Monte Carlo simulations to be able to estimate the model parameters. Thus Bayesian methods may be very useful, in particular if more complex data would be present. This could be especially true when longitudinal data must be harmonized.

The advantage of multiple imputations is on the other hand less clear a priori. Missing values are mainly “missing by design” because test results are just not implemented in certain studies. For instance, CCHS did not use the Buschke tests on memory, but only the Rey test was part of the design. This means that the missingness process may possibly be viewed as missing at random. In this setting likelihood approaches are appropriate and correct, which means that latent variable models would be appropriate when implemented with likelihood estimation. Furthermore, latent variable models can be viewed themselves as single imputation methods. They determine a latent variable and a relationship to the tests results which gives the opportunity to determine the test scores for the missing tests. The benefit of multiple imputation methods may possibly come from improved estimates of the standard errors. It would be of interest to investigate if multiple imputation approaches may provide other conclusions towards issues as heterogeneity.

## Overall Conclusions

This report provides empirical evidence to inform methods of combining complex constructs using aggregate data (AD) or individual participant data (IPD) meta-analysis of cognitive measures. Combining data on complex constructs such as cognition can be particularly challenging, and specialized methods of harmonization, including statistical harmonization, are required. The use of these methods of harmonization in the conduct of systematic reviews, however, is virtually nonexistent.

Overall there was a general consistency of our AD meta-analysis and IPD latent variable analysis results. Both methods underscored the difficulty of harmonizing these cognition data. There were multiple examples when using the AD methods, however, in which important heterogeneity was not identified. This masking of heterogeneity happened most often when using a T-score to standardize the cognition scores compared with a C-score or summary latent variable.

When one uses the T-score to create combinable data, there is an assumption that the sample characteristics are identical across studies. For the C-score this assumption is made only for a subgroup of participants. These assumptions may have no effect on an analysis of the data within a study but become an issue when pooling data across studies. The T-scores further reduce the variability within studies by standardizing the cognition constructs to age, sex, and education, but the C-scores are standardized to a common homogeneous age, sex, and education subgroup and the within- population variability related to age, sex and education remain. Within-study standardization to a common metric is generally not recommended given the potential differences in scale distributions and sample composition. The C-Score method aligns the within-study standardization procedure to a common subgroup but differences in measurement scales remain untested, with differences due to unadjusted variables. The latent variable approach is the only approach that allows for the examination of measurement invariance. We recommend item response theory (IRT) or factor-based type of models be used for harmonization procedures but also realize that this may not always be possible for particular research questions. New data collection efforts may be required to obtain the necessary individual-level data to confidently harmonize different indicators of common constructs.

The following guidance is suggested from our results:

- Very careful consideration of inferential equivalence needs to be undertaken prior to combining cognition data across studies. Qualitative harmonization is an essential step prior to statistical harmonization, when undertaking an AD or IPD meta-analysis.
- These results are likely applicable to meta-analyses of other complex constructs such as quality of life, depression, physical functioning, and nutritional status.
- Of the three methods of statistical harmonization for cognition data, T-score standardization is the least desirable compared with the C-score method or latent variable methods. The latent variable method is most desirable as it is the only method that allows the assessment of measurement invariance.
- Assessment of the assumptions underlying statistical harmonization is not possible without some individual-level data. This analysis is required to assess the potential for bias in combining complex outcomes using AD meta-analysis.
- Rigorous measurement approaches for evaluating measurement equivalence on item-level data using items response theory or latent variable approaches are recommended.