# Summary of One-Stage IDP Meta-Analysis

Appendix G Summary of one stage IPD meta-analysis

Variable in equation | Unified raw score | | t-score | | c-score
| Unadjusted | Adjusted^*^ | Selected | Adjusted^*^ | Selected | Adjusted^*^
| Coeff. (95% CI) | Coeff. (95% CI) | Coeff. (95% CI) | Coeff. (95% CI) | Coeff. (95% CI) | Coeff. (95% CI)
CCHS-Rey | 2.48 (1.88, 3.09) | 2.20 (1.61, 2.78) | 1.23 (0.77, 1.69) | 1.36 (0.88, 1.84) | 0.20 (0.15, 0.24) | 0.18 (0.13, 0.22)
CSHA-Rey | 2.48 (1.88, 3.09) | 2.20 (1.61, 2.78) | 1.23 (0.77, 1.69) | 1.36 (0.88, 1.84) | 0.20 (0.15, 0.24) | 0.18 (0.13, 0.22)
NuAge-Buschke free | 2.48 (1.88, 3.09) | 2.20 (1.61, 2.78) | 1.23 (0.77, 1.69) | 1.36 (0.88, 1.84) | 0.20 (0.15, 0.24) | 0.18 (0.13, 0.22)
CCHS-Rey | 2.45 (1.85, 3.05) | 2.17 (1.59, 2.76) | 1.20 (0.74, 1.65) | 1.34 (0.86, 1.82) | 0.19 (0.14, 0.24) | 0.17 (0.12, 0.22)
CSHA-Rey | 2.45 (1.85, 3.05) | 2.17 (1.59, 2.76) | 1.20 (0.74, 1.65) | 1.34 (0.86, 1.82) | 0.19 (0.14, 0.24) | 0.17 (0.12, 0.22)
NuAge-Buschke total | 2.45 (1.85, 3.05) | 2.17 (1.59, 2.76) | 1.20 (0.74, 1.65) | 1.34 (0.86, 1.82) | 0.19 (0.14, 0.24) | 0.17 (0.12, 0.22)
CCHS-Rey | 3.34 (2.65, 4.03) | 2.96 (2.29, 3.63) | 1.38 (0.93, 1.84) | 1.56 (1.08, 2.04) | 0.14 (0.17, 0.26) | 0.19 (0.15, 0.24)
CSHA-Buschke free | 3.34 (2.65, 4.03) | 2.96 (2.29, 3.63) | 1.38 (0.93, 1.84) | 1.56 (1.08, 2.04) | 0.14 (0.17, 0.26) | 0.19 (0.15, 0.24)
NuAge-Buschke free | 3.34 (2.65, 4.03) | 2.96 (2.29, 3.63) | 1.38 (0.93, 1.84) | 1.56 (1.08, 2.04) | 0.14 (0.17, 0.26) | 0.19 (0.15, 0.24)
CCHS-Rey | 3.32 (2.63, 4.01) | 2.94 (2.27, 3.61) | 1.35 (0.89, 1.80) | 1.54 (1.06, 2.02) | 0.21 (0.16, 0.26) | 0.19 (0.14, 0.24)
CSHA-Buschke free | 3.32 (2.63, 4.01) | 2.94 (2.27, 3.61) | 1.35 (0.89, 1.80) | 1.54 (1.06, 2.02) | 0.21 (0.16, 0.26) | 0.19 (0.14, 0.24)
NuAge-Buschke total | 3.32 (2.63, 4.01) | 2.94 (2.27, 3.61) | 1.35 (0.89, 1.80) | 1.54 (1.06, 2.02) | 0.21 (0.16, 0.26) | 0.19 (0.14, 0.24)
CCHS-Rey | 2.53 (1.90, 3.16) | 2.17 (1.55, 2.78) | 1.09 (0.64, 1.53) | 1.24 (0.76, 1.72) | 0.19 (0.14, 0.24) | 0.16 (0.12, 0.21)
CSHA-Buschke total | 2.53 (1.90, 3.16) | 2.17 (1.55, 2.78) | 1.09 (0.64, 1.53) | 1.24 (0.76, 1.72) | 0.19 (0.14, 0.24) | 0.16 (0.12, 0.21)
NuAge-Buschke free | 2.53 (1.90, 3.16) | 2.17 (1.55, 2.78) | 1.09 (0.64, 1.53) | 1.24 (0.76, 1.72) | 0.19 (0.14, 0.24) | 0.16 (0.12, 0.21)
CCHS-Rey | 2.51 (1.88, 3.13) | 2.15 (1.54, 2.76) | 1.06 (0.61, 1.51) | 1.22 (0.74, 1.70) | 0.18 (0.13, 0.23) | 0.16 (0.11, 0.21)
CSHA-Buschke total | 2.51 (1.88, 3.13) | 2.15 (1.54, 2.76) | 1.06 (0.61, 1.51) | 1.22 (0.74, 1.70) | 0.18 (0.13, 0.23) | 0.16 (0.11, 0.21)
NuAge-Buschke total | 2.51 (1.88, 3.13) | 2.15 (1.54, 2.76) | 1.06 (0.61, 1.51) | 1.22 (0.74, 1.70) | 0.18 (0.13, 0.23) | 0.16 (0.11, 0.21)
CCHS-HUI | 2.04 (1.36, 2.71) | 1.77 (1.08, 2.46) | 1.05 (0.59, 1.50) | 1.06 (0.58, 1.53) | 0.15 (0.10, 0.20) | 0.13 (0.08, 0.18)
CSHA-Rey | 2.04 (1.36, 2.71) | 1.77 (1.08, 2.46) | 1.05 (0.59, 1.50) | 1.06 (0.58, 1.53) | 0.15 (0.10, 0.20) | 0.13 (0.08, 0.18)
NuAge-Buschke free | 2.04 (1.36, 2.71) | 1.77 (1.08, 2.46) | 1.05 (0.59, 1.50) | 1.06 (0.58, 1.53) | 0.15 (0.10, 0.20) | 0.13 (0.08, 0.18)
CCHS-HUI | 2.01 (1.34, 2.68) | 1.75 (1.07, 2.44) | 1.01 (0.56, 1.47) | 1.04 (0.57, 1.52) | 0.14 (0.09, 0.19) | 0.12 (0.07, 0.17)
CSHA-Rey | 2.01 (1.34, 2.68) | 1.75 (1.07, 2.44) | 1.01 (0.56, 1.47) | 1.04 (0.57, 1.52) | 0.14 (0.09, 0.19) | 0.12 (0.07, 0.17)
NuAge-Buschke total | 2.01 (1.34, 2.68) | 1.75 (1.07, 2.44) | 1.01 (0.56, 1.47) | 1.04 (0.57, 1.52) | 0.14 (0.09, 0.19) | 0.12 (0.07, 0.17)
CCHS-HUI | 2.91 (2.16, 3.66) | 2.54 (1.78, 3.30) | 1.16 (0.72, 1.61) | 1.29 (0.81, 1.76) | 0.17 (0.12, 0.22) | 0.15 (0.10, 0.20)
CSHA-Buschke free | 2.91 (2.16, 3.66) | 2.54 (1.78, 3.30) | 1.16 (0.72, 1.61) | 1.29 (0.81, 1.76) | 0.17 (0.12, 0.22) | 0.15 (0.10, 0.20)
NuAge-Buschke free | 2.91 (2.16, 3.66) | 2.54 (1.78, 3.30) | 1.16 (0.72, 1.61) | 1.29 (0.81, 1.76) | 0.17 (0.12, 0.22) | 0.15 (0.10, 0.20)
CCHS-HUI | 2.89 (2.14, 3.63) | 2.53 (1.77, 3.28) | 1.13 (0.69, 1.58) | 1.27 (0.80, 1.75) | 0.16 (0.11, 0.21) | 0.14 (0.09, 0.19)
CSHA-Buschke free | 2.89 (2.14, 3.63) | 2.53 (1.77, 3.28) | 1.13 (0.69, 1.58) | 1.27 (0.80, 1.75) | 0.16 (0.11, 0.21) | 0.14 (0.09, 0.19)
NuAge-Buschke total | 2.89 (2.14, 3.63) | 2.53 (1.77, 3.28) | 1.13 (0.69, 1.58) | 1.27 (0.80, 1.75) | 0.16 (0.11, 0.21) | 0.14 (0.09, 0.19)
CCHS-HUI | 2.09 (1.40, 2.79) | 1.75 (1.04, 2.46) | 0.93 (0.48, 1.37) | 1.01 (0.53, 1.48) | 0.14 (0.09, 0.19) | 0.12 (0.07, 0.17)
CSHA-Buschke total | 2.09 (1.40, 2.79) | 1.75 (1.04, 2.46) | 0.93 (0.48, 1.37) | 1.01 (0.53, 1.48) | 0.14 (0.09, 0.19) | 0.12 (0.07, 0.17)
NuAge-Buschke free | 2.09 (1.40, 2.79) | 1.75 (1.04, 2.46) | 0.93 (0.48, 1.37) | 1.01 (0.53, 1.48) | 0.14 (0.09, 0.19) | 0.12 (0.07, 0.17)
CCHS-HUI | 2.06 (1.38, 2.75) | 1.73 (1.02, 2.43) | 0.90 (0.45, 1.35) | 1.00 (0.52, 1.47) | 0.13 (0.08, 0.18) | 0.11 (0.06, 0.16)
CSHA-Buschke total | 2.06 (1.38, 2.75) | 1.73 (1.02, 2.43) | 0.90 (0.45, 1.35) | 1.00 (0.52, 1.47) | 0.13 (0.08, 0.18) | 0.11 (0.06, 0.16)
NuAge-Buschke total | 2.06 (1.38, 2.75) | 1.73 (1.02, 2.43) | 0.90 (0.45, 1.35) | 1.00 (0.52, 1.47) | 0.13 (0.08, 0.18) | 0.11 (0.06, 0.16)

Latent variable: unadjusted: 0.088 (0.063, 0.113)

selected: 0.088 (0.063, 0.113)

adjusted: 0.095 (0.069, 0.121)

* Adjusted for Age, Gender, weight, height and alcohol