# Summary of Two-Stage IPD Meta-Analysis

Appendix F Summary of two stage IPD meta-analysis

Selection of memory tests | Type of outcome | Ranges of values from the analysis with different selections of covariates
| | Effect size | I^2^ | Q | p-value
CCHS:REY | Raw | 1.71 – 2.12 | 0.72 – 0.74 | 7.13 – 7.62 | 0.022 – 0.028
CSHA:REY | T-score | 1.09–1.20 | 0.64–0.71 | 5.58–6.91 | 0.032–0.061
NuAge: Buschke Free | C-score | 0.13–0.16 | 0.74–0.75 | 7.75–8.16 | 0.017–0.021
CCHS:REY | Raw | 1.69–1.72 | 0.78–0.82 | 8.95–11.33 | 0.003–0.011
CSHA:REY | T-score | 0.96–1.03 | 0.74–0.76 | 7.62–8.46 | 0.015–0.022
NuAge: Buschke Total | C-score | 0.15–0.16 | 0.69–0.75 | 6.49–8.10 | 0.017–0.039
CCHS:REY | Raw | 2.44–3.05 | 0.90–0.92 | 20.96–26.76 | <0.001
CSHA:Buschke Free | T-score | 1.36–1.40 | 0.85–0.87 | 12.97–15.48 | <0.001–0.002
NuAge: Buschke Free | C-score | 0.15–0.18 | 0.84–0.86 | 12.46–14.34 | 0.001–0.002
CCHS:REY | Raw | 2.37–2.78 | 0.91–0.94 | 22.37–31.14 | <0.001
CSHA:Buschke Free | T-score | 1.30–1.74 | 0.88–0.88 | 16.03–16.23 | <0.001
NuAge: Buschke Total | C-score | 0.16–0.18 | 0.81–0.86 | 10.50–14.28 | 0.001–0.005
CCHS:REY | Raw | 1.46–2.04 | 0.68–0.73 | 6.32–7.34 | 0.025–0.043
CSHA:Buschke Total | T-score | 0.95–1.06 | 0.43–0.63 | 3.48–3.57 | 0.068–0.175
NuAge: Buschke Free | C-score | 0.11–0.15 | 0.71–0.71 | 6.84–6.93 | 0.031–0.033
CCHS:REY | Raw | 1.32–1.63 | 0.74–0.82 | 7.58–11.38 | 0.023–0.003
CSHA:Buschke Total | T-score | 0.79–0.88 | 0.67–0.68 | 6.06–6.24 | 0.044–0.048
NuAge: Buschke Total | C-score | 0.12–0.15 | 0.64–0.73 | 5.62–7.31 | 0.026–0.060
CCHS:HUI | Raw | 1.48–1.82 | 0.74–0.75 | 7.59–7.96 | 0.019–0.023
CSHA:REY | T-score | 0.94–1.08 | 0.67–0.72 | 6.03–7.12 | 0.029–0.049
NuAge: Buschke Free | C-score | 0.11–0.13 | 0.76–0.77 | 8.29–8.54 | 0.014–0.016
CCHS:HUI | Raw | 1.36–1.45 | 0.78–0.82 | 9.13–11.38 | 0.003–0.010
CSHA:REY | T-score | 0.85–0.89 | 0.74–0.77 | 7.77–8.71 | 0.013–0.021
NuAge: Buschke Total | C-score | 0.12–0.13 | 0.73–0.78 | 7.51–9.28 | 0.010–0.023
CCHS:HUI | Raw | 2.28–2.85 | 0.91–0.93 | 22.13–28.99 | <0.001
CSHA:Buschke Free | T-score | 1.22–1.30 | 0.86–0.88 | 14.47–17.30 | <0.001–0.001
NuAge: Buschke Free | C-score | 0.12–0.15 | 0.86–0.89 | 14.72–18.36 | <0.001–0.001
CCHS:HUI | Raw | 2.22–2.59 | 0.91–0.94 | 23.38–32.89 | <0.001
CSHA:Buschke Free | T-score | 1.07–1.17 | 0.89–0.89 | 17.33–18.00 | <0.001
NuAge: Buschke Total | C-score | 0.13–0.14 | 0.85–0.89 | 13.40–18.89 | <0.001–0.001
CCHS:HUI | Raw | 1.28–1.77 | 0.65–0.73 | 5.77–7.53 | 0.023–0.056
CSHA:Buschke Total | T-score | 0.83–0.95 | 0.39–0.59 | 3.25–4.84 | 0.089–0.197
NuAge: Buschke Free | C-score | 0.09–0.13 | 0.61–0.66 | 5.11–5.81 | 0.055–0.078
CCHS:HIU | Raw | 1.15–1.41 | 0.71–0.82 | 6.84–11.06 | 0.004–0.033
CSHA:Buschke Total | T-score | 0.71–0.77 | 0.64–0.66 | 5.48–5.81 | 0.055–0.065
NuAge: Buschke Total | C-score | 0.10–0.12 | 0.54–0.70 | 4.36–6.67 | 0.036–0.113
CCHS:HIU | Latent variable | 0.08–0.08 | .89–.89 | 17.76–17.83 | <0.001
CSHA:Buschke Total | Latent variable | 0.08–0.08 | .89–.89 | 17.76–17.83 | <0.001
NuAge: Buschke Total | Latent variable | 0.08–0.08 | .89–.89 | 17.76–17.83 | <0.001