# Additional Regression Results

Appendix E. Table 1 Summary of relationship of T scores for cognitive measures with variables of interest

Variable | Description | CCHS | | CSHA n=1730 | | | NuAge
| | REY | HUI | REY | BUSC1 | BUSC_T | BUSC1 | BUSC_T
G_Age | Age in years (n) | 7,060 | 7,058 | 1,488 | 1,488 | 1,488 | 432 | 432
| Intercept | 50.0000 | 50.0000 | 50.0000 | 50.0000 | 50.0000 | 50.0000 | 50.0000
| Beta | 0.0000 | 0.0000 | −0.0000 | −0.0000 | 0.0000 | 0.0000 | 0.0000
| R-square | 0.0000 | 0.0000 | 0.0000 | 0.0000 | 0.0000 | 0.0000 | 0.0000
| p-value | 1.0000 | 1.0000 | 1.0000 | 1.0000 | 1.0000 | 1.0000 | 1.0000
G_129 | Gender (n) | 7,060 | 7,058 | 1,488 | 1,488 | 1,488 | 432 | 432
| Intercept | 50.0000 | 50.0000 | 50.0000 | 50.0000 | 50.0000 | 50.0000 | 50.0000
| Beta (Ref: male) | −0.0000 | −0.0000 | 0.0000 | 0.0000 | 0.0000 | −0.0000 | −0.00000
| R-square | 0.0000 | 0.0000 | 0.0000 | 0.0000 | 0.0000 | 0.0000 | 0.0000
| p-value | 1.0000 | 1.0000 | 1.0000 | 1.0000 | 1.0000 | 1.0000 | 1.0000
G_161_C | Highest level of education (n) | 7,060 | 7,060 | 1,488 | 1,488 | 1,488 | 432 | 432
| Intercept | 50.0000 | 50.0000 | 49.9816 | 50.0795 | 49.9984 | 50.0940 | 50.2683
| Beta (Ref: Low (0–8)
| Moderate (9–13) | 0.0000 | 0.0000 | 0.0588 | −0.2545 | 0.0053 | −0.1570 | −0.4481
| High (14+) | 0.0000 | 0.0000 | −0.0548 | 0.2372 | −0.0049 | −0.0573 | −0.1635
| R-square | 0.0000 | 0.0000 | 0.0000 | 0.0003 | 0.0000 | 0.0000 | 0.0003
| p-value | 1.0000 | 1.0000 | 0.9892 | 0.8153 | 0.9999 | 0.9921 | 0.9375
G_297 | Country of birth (n) | 7,058 | 7,056 | 1,488 | 1,488 | 1,488 | 432 | 432
| Intercept | 48.7473 | 49.6602 | 49.0965 | 49.8638 | 49.5637 | 50.8868 | 51.1381
| Beta (Ref: other country) | 1.5457 | 0.4194 | 1.3566 | 0.2045 | 0.6551 | −0.9899 | −1.2705
| R-square | 0.0036 | 0.0003 | 0.0041 | 0.0001 | 0.0010 | 0.0009 | 0.0015
| p-value | < 0.0001 | 0.1697 | 0.0135 | 0.7100 | 0.2334 | 0.5303 | 0.4205
G_940 | Ever/current smoked cigarettes (n) | 7,058 | 7,056 | 1,301^*^ | 1,301^*^ | 1,301 | 432 | 432
| Intercept | 49.9776 | 50.4173 | 50.5273 | 50.5487 | 50.2103 | 49.7371 | 49.7214
| Beta (Ref: never) | 0.0308 | −0.6094 | −0.7712 | −0.9033 | −0.2868 | 0.5824 | 0.6171
| R-square | 0.000002 | 0.0008 | 0.0015 | 0.0020 | 0.0002 | 0.0008 | 0.0009
| p-value | 0.9039 | 0.0170 | 0.1657 | 0.1071 | 0.6029 | 0.5475 | 0.5239
G_2526 | Ever/current alcohol consumption (n) | 7,060 | 7,058 | 1,289 | 1,289 | 1,289 | 432 | 432
| Intercept | 48.2874 | 50.3179 | 50.2092 | 50.5104 | 50.3687 | 44.1332 | 47.9754
| Beta (Ref: never) | 1.8590 | −0.3451 | 0.2516 | −1.1290 | −1.1986 | 6.1665 | 2.1281
| R-square | 0.0025 | 0.00009 | 0.0001 | 0.0022 | 0.0025 | 0.0176 | 0.0021
| p-value | <0.0001 | 0.4349 | 0.7083 | 0.0911 | 0.0726 | 0.0057 | 0.3421
G_355 | Standing height in centimeter (n) | 7,024 | 7,022 | 1,377 | 1,377 | 1,377 | 432 | 432
| Intercept | 47.3332 | 50.5118 | 46.5496 | 47.9305 | 53.4555 | 41.2094 | 34.9620
| Beta | 0.0161 | −0.0031 | 0.0223 | 0.0136 | −0.0204 | 0.0544 | 0.0931
| R-square | 0.0002 | 0.00001 | 0.0005 | 0.0002 | 0.0004 | 0.0025 | 0.0074
| p-value | 0.1895 | 0.8024 | 0.4151 | 0.6181 | 0.4534 | 0.2973 | 0.0742
G_217 | Weight in Kg | 6,956 | 6,954 | 1,420 | 1,420 | 1,420 | 432 | 432
| Intercept | 49.1409 | 50.2085 | 49.2215 | 46.6716 | 49.0394 | 52.5501 | 47.3578
| Beta | 0.0118 | −0.0026 | 0.0123 | 0.0526 | 0.0158 | −0.0351 | 0.0363
| R-square | 0.0003 | 0.00002 | 0.0003 | 0.0053 | 0.0005 | 0.0026 | 0.0028
| p-value | 0.1220 | 0.7346 | 0.5177 | 0.0058 | 0.4100 | 0.2907 | 0.2736
G_162 | Body mass index (N) | 6,924 | 6,922 | 1,357 | 1,357 | 1,357 | 432 | 432
| Intercept | 49.5068 | 50.3061 | 50.3508 | 46.5906 | 48.8816 | 55.4833 | 49.9240
| Beta | 0.0200 | −0.0108 | −0.0061 | 0.1481 | 0.0520 | −0.1973 | 0.0027
| R-square | 0.00009 | 0.00003 | 0.0000 | 0.0046 | 0.0006 | 0.0082 | 0.0000
| p-value | 0.4228 | 0.6637 | 0.9186 | 0.0127 | 0.3816 | 0.0603 | 0.9793
G_326 | Occurrence of high blood pressure(N) | 7,058 | 7,055 | 1,349 | 1,349 | 1,349 | 432 | 432
| Intercept | 50.1377 | 49.99 | 50.2537 | 49.7083 | 49.6610 | 50.429 | 49.7764
| Beta (Ref: never) | −0.2403 | 0.0318 | −0.5059 | 1.0007 | 1.1146 | −0.8869 | 0.4690
| R-square | 0.0001 | 0.000002 | 0.0006 | 0.0024 | 0.0031 | 0.0020 | 0.0006
| p-value | 0.3166 | 0.8945 | 0.3655 | 0.0734 | 0.0406 | 0.3578 | 0.6269
G_290 | Occurrence of diabetes (N) | 7,058 | 7,056 | 1,455 | 1,455 | 1,455 | 432 | 432
| Intercept | 50.2658 | 50.1048 | 50.0894 | 49.9876 | 49.8359 | 49.8600 | 49.7602
| Beta (Ref: never) | −1.5012 | −0.5819 | −0.8708 | 0.1272 | 0.9099 | 1.5125 | 2.5900
| R-square | 0.0033 | 0.0005 | 0.0009 | 0.0000 | 0.0009 | 0.0019 | 0.0056
| p-value | <0.0001 | 0.0621 | 0.2621 | 0.8702 | 0.2451 | 0.3628 | 0.1188
G_388 | Occurrence of myocardial infarction (N) | 7,046 | 7,043 | 1,431 | 1,431 | 1,431 | 424 | 424
| Intercept | 50.1058 | 50.1037 | 50.1462 | 50.0846 | 49.9405 | 49.8041 | 50.0110
| Beta (Ref: never) | −0.7705 | −0.7546 | −0.6850 | 0.3375 | 1.3464 | 1.5824 | −0.0490
| R-square | 0.0006 | 0.0006 | 0.0006 | 0.0002 | 0.0026 | 0.0029 | 0.0000
| p-value | 0.0333 | 0.0370 | 0.3447 | 0.6382 | 0.0543 | 0.2690 | 0.9725
G_245_CB | Categorical indicator of the participants level of physical activity using CSHA categories (3 categories) (N) | 7060 | 7058 | 1271 | 1271 | 1271 | 432 | 432
| Intercept | 48.9042 | 49.5623 | 49.2264 | 48.5627 | 49.1926 | 51.6882 | 51.1951
| Beta (Ref: none)
| Low level | 0.4616 | −0.7936 | 1.5737 | 2.3309 | 1.7180 | −1.9179 | 0.2914
| Moderate or high level | 1.4369 | 0.7204 | 2.4643 | 3.6444 | 1.8030 | −1.8856 | −1.5525
| R-square | 0.0032 | 0.0025 | 0.0127 | 0.0279 | 0.0077 | 0.0034 | 0.0048
| p-value | < 0.0001 | 0.0001 | 0.0003 | < 0.0001 | 0.0074 | 0.4811 | 0.3531
G_245_CO | Categorical indicator of the participants level of physical activity using CSHA categories (4 categories) (N) | 7,060 | 7,058 | 1,271 | 1,271 | 1,271 | 432 | 432
| Intercept | 48.9042 | 49.5623 | 49.2264 | 48.5627 | 49.1926 | 51.6882 | 51.1951
| Beta (Ref: none)
| Low level | 0.4616 | −0.7936 | 1.5737 | 2.3309 | 1.7180 | −1.9179 | 0.2914
| Moderate level | 1.2255 | 0.6285 | 2.2189 | 3.3708 | 1.5214 | −1.3698 | −1.4205
| High level | 2.1000 | 1.0085 | 3.2841 | 4.5582 | 2.7435 | −2.8115 | −1.7894
| R-square | 0.0043 | 0.0027 | 0.0134 | 0.0288 | 0.0086 | 0.0072 | 0.0051
| p-value | < 0.0001 | 0.0002 | 0.0007 | < 0.0001 | 0.0118 | 0.3781 | 0.5346

Appendix E. Table 2 Summary of relationship of centered scores for cognitive measures with variables of interest

Variable | Description | CCHS | | CSHA n=1730 | | | NuAge
| | REY | HUI | REY | BUSC1 | BUSC_T | BUSC1 | BUSC_T
G_Age | Age in years (n) | 7,106 | 7,103 | 1,497 | 1,730 | 1,730 | 432 | 432
| Intercept | 3.6550 | 1.086 | 1.6300 | 2.5670 | 2.0236 | 2.3318 | 2.7491
| Beta | −0.0531 | −0.0155 | −0.0239 | −0.0340 | −0.0251 | −0.0368 | −0.0423
| R-square | 0.0869 | 0.0073 | 0.0332 | 0.0615 | 0.0391 | 0.0184 | 0.0113
| p-value | <0.0001 | <0.0001 | <0.0001 | <0.0001 | <0.0001 | 0.0048 | 0.0269
G_129 | Gender (n) | 7,106 | 7,104 | 1,497 | 1,730 | 1,730 | 432 | 432
| Intercept | −0.4398 | −0.0477 | −0.3303 | −0.1055 | 0.1260 | −0.6811 | −0.6629
| Beta (Ref: male) | 0.3522 | −0.0092 | 0.0967 | −0.0590 | −0.1701 | 0.5660 | 0.5537
| R-square | 0.0272 | 0.00002 | 0.0027 | 0.0009 | 0.0087 | 0.0693 | 0.0310
| p-value | <0.0001 | 0.7203 | 0.0442 | 0.2133 | 0.0001 | <0.0001 | 0.0002
G_161_C | Highest level of education (n) | 7,060 | 7,058 | 1,488 | 1,719 | 1,719 | 432 | 432
| Intercept | −0.7151 | −0.1701 | −0.4317 | −0.1169 | 0.0177 | −0.5738 | −0.6508
| Beta (Ref: Low (0–8)
| Moderate (9–13) | 0.4248 | 0.0912 | 0.2440 | −0.0541 | −0.0007 | 0.1798 | 0.2251
| High (14+) | 0.7367 | 0.1883 | 0.4610 | −0.0057 | 0.0342 | 0.2931 | 0.4668
| R-square | 0.0660 | 0.0044 | 0.0313 | 0.0007 | 0.0002 | 0.0084 | 0.0110
| p-value | <0.0001 | <0.0001 | <0.0001 | 0.5271 | 0.8773 | 0.1632 | 0.0939
G_297 | Country of birth (n) | 7,104 | 7,102 | 1,497 | 1,730 | 1,730 | 432 | 432
| Intercept | −0.3347 | −0.0770 | −0.3763 | −0.1980 | −0.0388 | −0.3535 | −0.2498
| Beta (Ref: other country) | 0.1211 | 0.0297 | 0.1596 | 0.0824 | 0.0863 | −0.0264 | −0.1292
| R-square | 0.0020 | 0.00012 | 0.0070 | 0.0016 | 0.0021 | 0.0001 | 0.0006
| p-value | 0.0002 | 0.3598 | 0.0012 | 0.0922 | 0.0571 | 0.8759 | 0.6018
G_940 | Ever/current smoked cigarettes (n) | 7,104 | 7,102 | 1,309^*^ | 1,521^*^ | 1,521^*^ | 432 | 432
| Intercept | −0.2212 | −0.0226 | −0.2327 | −0.1505 | −0.0302 | −0.2887 | −0.2912
| Beta (Ref: never) | −0.0227 | −0.0441 | −0.0421 | 0.0427 | 0.1244 | −0.1960 | −0.1649
| R-square | 0.0001 | 0.0004 | 0.0005 | 0.0005 | 0.0050 | 0.0083 | 0.0027
| p-value | 0.3987 | 0.1034 | 0.4024 | 0.3902 | 0.0059 | 0.0589 | 0.2779
G_2526 | Ever/current alcohol consumption (n) | 7,106 | 7,104 | 1,297 | 1,507 | 1,507 | 432 | 432
| Intercept | −0.4540 | −0.0589 | −0.2543 | −0.1232 | 0.0145 | −0.9818 | −0.7094
| Beta (Ref: never) | 0.2360 | 0.0065 | 0.0331 | 0.0020 | 0.0564 | 0.6356 | 0.3614
| R-square | 0.0036 | 0.000003 | 0.0002 | 0.0000 | 0.0007 | 0.0162 | 0.0025
| p-value | <0.0001 | 0.8907 | 0.5853 | 0.9736 | 0.2982 | 0.0080 | 0.3041
G_355 | Standing height in centimeter (n) | 7,070 | 7,068 | 1,386 | 1,600 | 1,600 | 432 | 432
| Intercept | 0.9935 | −0.2234 | −0.5207 | −0.9502 | −0.9520 | 1.7744 | 0.2221
| Beta | −0.0074 | 0.0010 | 0.0017 | 0.0051 | 0.0061 | −0.0133 | −0.0036
| R-square | 0.0046 | 0.00009 | 0.0003 | 0.0028 | 0.0048 | 0.0131 | 0.0005
| p-value | <0.0001 | 0.4292 | 0.4994 | 0.0341 | 0.0055 | 0.0172 | 0.6574
G_217 | Weight in Kg | 7,000 | 6,998 | 1,428 | 1,654 | 1,654 | 432 | 432
| Intercept | −0.1766 | −0.1044 | −0.3992 | −0.6849 | −0.4315 | 0.4269 | −0.2449
| Beta | −0.0008 | 0.0007 | 0.0020 | 0.0085 | 0.0070 | −0.0111 | −0.0017
| R-square | 0.0001 | 0.0001 | 0.0010 | 0.0154 | 0.0121 | 0.0224 | 0.0002
| p-value | 0.3389 | 0.3780 | 0.2332 | <0.0001 | <0.0001 | 0.0018 | 0.7502
G_162 | Body mass index (N) | 6,968 | 6,966 | 1,365 | 1,576 | 1,576 | 432 | 432
| Intercept | −0.3991 | −0.0702 | −0.3295 | −0.6260 | −0.2715 | 0.2293 | −0.3264
| Beta | 0.0063 | 0.0007 | 0.0032 | 0.0208 | 0.0127 | −0.0218 | −0.0014
| R-square | 0.0008 | 0.00001 | 0.0003 | 0.0101 | 0.0044 | 0.0087 | 0.0000
| p-value | 0.0165 | 0.7784 | 0.5477 | <0.0001 | 0.0081 | 0.0529 | 0.9320
G_326 | Occurrence of high blood pressure(N) | 7,104 | 7,102 | 1,358 | 1,561 | 1,561 | 432 | 432
| Intercept | −0.1928 | −0.0414 | −0.2530 | −0.1601 | 0.0055 | −0.3125 | −0.3702
| Beta (Ref: never) | −0.0773 | −0.0197 | −0.0290 | 0.0616 | 0.0556 | −0.1355 | 0.0096
| R-square | 0.0013 | 0.00008 | 0.0002 | 0.0010 | 0.0010 | 0.0040 | 0.0000
| p-value | 0.0022 | 0.4397 | 0.5650 | 0.2144 | 0.2168 | 0.1905 | 0.9494
G_290 | Occurrence of diabetes (N) | 7,104 | 7,102 | 1,464 | 1,691 | 1,691 | 432 | 432
| Intercept | −0.1962 | −0.0391 | −0.2633 | −0.1452 | 0.0026 | −0.3818 | −0.3905
| Beta (Ref: never) | −0.2258 | −0.0769 | −0.0590 | 0.0118 | 0.0918 | 0.0508 | 0.2686
| R-square | 0.0067 | 0.0008 | 0.0005 | 0.0000 | 0.0012 | 0.0002 | 0.0025
| p-value | <0.0001 | 0.0202 | 0.3994 | 0.8624 | 0.1484 | 0.7758 | 0.3032
G_388 | Occurrence of myocardial infarction (N) | 7,092 | 7,090 | 1,440 | 1,665 | 1,665 | 424 | 424
| Intercept | −0.1993 | −0.0374 | −0.2535 | −0.1390 | 0.0116 | −0.4033 | −0.3721
| Beta (Ref: never) | −0.2927 | −0.1172 | −0.0768 | 0.0456 | 0.1173 | 0.2247 | 0.0787
| R-square | 0.0083 | 0.0013 | 0.0010 | 0.0003 | 0.0025 | 0.0051 | 0.0003
| p-value | <0.0001 | 0.0023 | 0.2391 | 0.4740 | 0.0434 | 0.1436 | 0.7234
G_245_CB | Categorical indicator of the participants level of physical activity using CSHA categories (3 categories) (N) | 7,106 | 7,104 | 1,279 | 1,484 | 1,484 | 432 | 432
| Intercept | −0.4286 | −0.1310 | −0.3772 | −0.2937 | −0.0717 | −0.2695 | −0.2689
| Beta (Ref: never)
| Low level | 0.1079 | −0.0670 | 0.2251 | 0.2348 | 0.1629 | −0.0041 | 0.2790
| Moderate or high level | 0.2480 | 0.1174 | 0.2946 | 0.3989 | 0.2256 | −0.1358 | −0.1593
| R-square | 0.0082 | 0.0039 | 0.0231 | 0.0357 | 0.0141 | 0.0026 | 0.0076
| p-value | <0.0001 | <0.0001 | <0.0001 | <0.0001 | <0.0001 | 0.5737 | 0.1928
G_245_CO | Categorical indicator of the participants level of physical activity using CSHA categories (4 categories) (N) | 7,106 | 7,104 | 1,279 | 1,484 | 1,484 | 432 | 432
| Intercept | −0.4286 | −0.1310 | −0.3772 | −0.2937 | −0.0717 | −0.2695 | −0.2689
| Beta (Ref: none)
| Low level | 0.1079 | −0.0670 | 0.2251 | 0.2348 | 0.1629 | −0.0041 | 0.2790
| Moderate level | 0.2077 | 0.1005 | 0.2619 | 0.3530 | 0.1810 | −0.0728 | −0.1338
| High level | 0.3742 | 0.1706 | 0.4044 | 0.5512 | 0.3736 | −0.2487 | −0.2051
| R-square | 0.0115 | 0.0045 | 0.0246 | 0.0382 | 0.0169 | 0.0075 | 0.0080
| p-value | <0.0001 | <0.0001 | <0.0001 | <0.0001 | <0.0001 | 0.3602 | 0.3274