# Meta-Analysis Results Weighted Mean Difference Analysis

Appendix D. Table 1 Summary of Traditional Meta-Analysis Results for Rey from CCHS and CSHA and Buschke Free from NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.16 (0.01, 0.30) | 0.78 | 8.96 | 0.01
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.16 (0.01, 0.30) | 0.75 | 7.84 | 0.02
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.11 (−0.02, 0.24) | 0.72 | 7.18 | 0.03
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.11 (−0.02, 0.23) | 0.66 | 5.81 | 0.06
T-Score – Weighted Mean Difference | Unadjusted^†^ | 1.18 (0.05, 2.32) | 0.64 | 5.45 | 0.06
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 1.19 (0.11, 2.27) | 0.55 | 4.47 | 0.11
T-Score – Weighted Mean Difference | Common Set of Covariates | 1.09 (−0.20, 2.39) | 0.67 | 5.98 | 0.05
C-Score – Weighted Mean Difference | Unadjusted | 0.16 (0.03, 0.29) | 0.73 | 7.46 | 0.02
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.17 (0.04, 0.30) | 0.70 | 6.69 | 0.04
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.11 (−0.01, 0.22) | 0.63 | 5.33 | 0.07

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 2 Summary of traditional meta-analysis results for rey from CCHS and CSHA and Buschke total from NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.13 (−0.04, 0.30) | 0.84 | 12.20 | 0.002
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (−0.04, 0.30) | 0.82 | 10.99 | 0.004
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.10 (−0.04, 0.24) | 0.75 | 8.14 | 0.02
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.10 (−0.04, 0.23) | 0.72 | 7.06 | 0.03
T-Score – Weighted Mean Difference | Unadjusted^†^ | 0.89 (−0.55, 2.34) | 0.78 | 9.10 | 0.01
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.89 (−0.55, 2.33) | 0.75 | 7.86 | 0.02
T-Score – Weighted Mean Difference | Common Set of Covariates | 0.98 (−0.45, 2.41) | 0.72 | 7.21 | 0.03
C-Score – Weighted Mean Difference | Unadjusted | 0.15 (−0.001, 0.30) | 0.78 | 9.10 | 0.01
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.15 (−0.002, 0.31) | 0.76 | 8.18 | 0.02
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.12 (0.001, 0.23) | 0.60 | 4.95 | 0.08

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 3 Summary of traditional meta-analysis results for rey from CCHS and Buschke free from CSHA and NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.18 (−0.01, 0.36) | 0.88 | 16.46 | <0.001
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.18 (0.0001, 0.36) | 0.85 | 13.37 | 0.001
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.12 (−0.04, 0.29) | 0.85 | 13.0 | 0.002
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.13 (−0.05, 0.31) | 0.85 | 12.9 | 0.002
T-Score – Weighted Mean Difference | Unadjusted^†^ | 1.40 (−0.33, 3.13) | 0.85 | 13.51 | 0.001
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 1.44 (−0.25, 3.13) | 0.83 | 11.56 | 0.003
T-Score – Weighted Mean Difference | Common Set of Covariates | 1.38 (−0.53, 3.28) | 0.85 | 13.43 | 0.001
C-Score – Weighted Mean Difference | Unadjusted | 0.18 (0.01, 0.36) | 0.86 | 14.45 | 0.001
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.19 (0.03, 0.35) | 0.83 | 11.5 | 0.003
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.13 (−0.04, 0.30) | 0.84 | 12.22 | 0.002

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 4 Summary of traditional meta-analysis results for rey from CCHS, Buschke free from CSHA and Buschke total from NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.16 (−0.04, 0.35) | 0.90 | 20.32 | <0.001
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.16 (−0.04, 0.36) | 0.88 | 16.67 | <0.001
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.12 (−0.06, 0.29) | 0.86 | 13.98 | 0.001
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.12 (−0.06, 0.31) | 0.86 | 14.29 | 0.001
T-Score – Weighted Mean Difference | Unadjusted^†^ | 1.14 (−0.79, 3.06) | 0.89 | 17.42 | <0.001
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 1.18 (−0.72, 3.08) | 0.87 | 15.26 | <0.001
T-Score – Weighted Mean Difference | Common Set of Covariates | 1.28 (−0.72, 3.27) | 0.86 | 14.74 | 0.001
C-Score – Weighted Mean Difference | Unadjusted | 0.17 (−0.02, 0.36) | 0.87 | 15.90 | <0.001
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.18 (−0.007, 0.36) | 0.84 | 12.85 | 0.002
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.14 (−0.04, 0.31) | 0.83 | 11.56 | 0.002

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 5 Summary of traditional meta-analysis results for rey from CCHS, Buschke total from CSHA and Buschke free from NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.15 (0.02, 0.27) | 0.73 | 7.35 | 0.03
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.15 (0.02, 0.28) | 0.71 | 6.80 | 0.03
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.09 (−0.01, 0.20) | 0.63 | 5.47 | 0.07
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.10 (−0.008, 0.21) | 0.61 | 5.18 | 0.08
T-Score – Weighted Mean Difference | Unadjusted^†^ | 1.08 (0.27, 1.88) | 0.43 | 3.48 | 0.18
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 1.12 (0.31, 1.94) | 0.41 | 3.37 | 0.19
T-Score – Weighted Mean Difference | Common Set of Covariates | 1.06 (−0.12, 2.23) | 0.65 | 5.35 | 0.07
C-Score – Weighted Mean Difference | Unadjusted | 0.15 (0.05, 0.26) | 0.70 | 6.61 | 0.04
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.16 (0.05, 0.27) | 0.68 | 6.27 | 0.04
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.10 (0.006, 0.20) | 0.57 | 4.68 | 0.10

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 6 Summary of traditional meta-analysis results for rey from CCHS and Buschke total from CSHA and NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.12 (−0.03, 0.27) | 0.81 | 10.51 | 0.005
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.12 (−0.03, 0.28) | 0.80 | 9.89 | 0.007
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.09 (−0.03, 0.20) | 0.69 | 6.39 | 0.04
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.09 (−0.03, 0.22) | 0.69 | 6.42 | 0.04
T-Score – Weighted Mean Difference | Unadjusted^†^ | 0.77 (−0.42, 1.95) | 0.71 | 6.93 | 0.03
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.81 (−0.39, 2.01) | 0.70 | 6.67 | 0.04
T-Score – Weighted Mean Difference | Common Set of Covariates | 0.94 (−0.37, 2.26) | 0.70 | 6.57 | 0.04
C-Score – Weighted Mean Difference | Unadjusted | 0.14 (0.02, 0.27) | 0.76 | 8.31 | 0.02
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.15 (0.02, 0.27) | 0.75 | 7.83 | 0.02
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.11 (0.01, 0.21) | 0.54 | 4.35 | 0.11

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 7 Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA, rey from CSHA and Buschke free from NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.13 (−0.02, 0.28) | 0.80 | 9.86 | 0.007
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (−0.02, 0.27) | 0.75 | 8.10 | 0.02
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.09 (−0.04, 0.22) | 0.74 | 7.58 | 0.02
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.09 (−0.03, 0.22) | 0.66 | 5.83 | 0.054
T-Score – Weighted Mean Difference | Unadjusted^†^ | 1.07 (−0.11, 2.26) | 0.66 | 5.9 | 0.053
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 1.05 (−0.06, 2.16) | 0.57 | 4.61 | 0.10
T-Score – Weighted Mean Difference | Common Set of Covariates | 0.95 (−0.35, 2.25) | 0.67 | 6.02 | 0.049
C-Score – Weighted Mean Difference | Unadjusted | 0.13 (−0.002, 0.27) | 0.75 | 7.95 | 0.02
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (0.002, 0.27) | 0.70 | 6.64 | 0.04
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.10 (−0.02, 0.21) | 0.62 | 5.30 | 0.07

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 8 Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA, rey from CSHA and Buschke total from NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.11 (−0.06, 0.28) | 0.84 | 12.67 | 0.002
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.11 (−0.06, 0.28) | 0.81 | 10.77 | 0.005
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.08 (−0.06, 0.22) | 0.77 | 8.61 | 0.01
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.08 (−0.05, 0.22) | 0.71 | 6.98 | 0.03
T-Score – Weighted Mean Difference | Unadjusted^†^ | 0.80 (−0.67, 2.27) | 0.78 | 9.21 | 0.01
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.80 (−0.65, 2.22) | 0.74 | 7.66 | 0.02
T-Score – Weighted Mean Difference | Common Set of Covariates | 0.85 (−0.58, 2.27) | 0.72 | 7.14 | 0.03
C-Score – Weighted Mean Difference | Unadjusted | 0.12 (−0.04, 0.28) | 0.80 | 9.84 | 0.007
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.12 (−0.04, 0.28) | 0.76 | 8.39 | 0.02
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.11 (−0.02, 0.22) | 0.61 | 5.10 | 0.08

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 9 Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA and Buschke free from CSHA and NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.15 (−0.06, 0.36) | 0.90 | 20.62 | <0.001
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.15 (−0.05, 0.35) | 0.88 | 16.54 | <0.001
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.11 (−0.08, 0.30) | 0.88 | 16.56 | <0.001
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.12 (−0.07, 0.31) | 0.86 | 14.53 | 0.001
T-Score – Weighted Mean Difference | Unadjusted^†^ | 1.30 (−0.52, 3.12) | 0.87 | 14.85 | 0.001
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 1.32 (−0.48, 3.11) | 0.85 | 12.91 | 0.002
T-Score – Weighted Mean Difference | Common Set of Covariates | 1.24 (−0.77, 3.25) | 0.87 | 14.96 | 0.001
C-Score – Weighted Mean Difference | Unadjusted | 0.15 (−0.04, 0.35) | 0.89 | 18.70 | <0.001
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.15 (−0.03, 0.34) | 0.87 | 14.88 | 0.001
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.12 (−0.06, 0.30) | 0.85 | 13.10 | 0.001

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 10 Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA, Buschke free from CSHA and Buschke total from NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.13 (−0.09, 0.35) | 0.92 | 23.61 | <0.001
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (−0.09, 0.35) | 0.90 | 19.36 | <0.001
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.11 (−0.09, 0.30) | 0.89 | 17.66 | <0.001
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.11 (−0.09, 0.31) | 0.87 | 15.77 | <0.001
T-Score – Weighted Mean Difference | Unadjusted^†^ | 1.05 (−0.95, 3.04) | 0.89 | 18.51 | <0.001
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 1.07 (−0.91, 3.05) | 0.88 | 16.28 | <0.001
T-Score – Weighted Mean Difference | Common Set of Covariates | 1.14 (−0.95, 3.23) | 0.88 | 16.17 | <0.001
C-Score – Weighted Mean Difference | Unadjusted | 0.13 (−0.09, 0.35) | 0.90 | 20.44 | <0.001
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.14 (−0.07, 0.34) | 0.88 | 16.53 | <0.001
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.12 (−0.07, 0.31) | 0.84 | 12.59 | 0.002

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 11 Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA, Buschke total from CSHA and Buschke free from NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.12 (−0.004, 0.24) | 0.72 | 7.01 | 0.03
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.12 (−0.001, 0.24) | 0.70 | 6.04 | 0.049
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.09 (−0.03, 0.21) | 0.68 | 6.30 | 0.04
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.09 (−0.02, 0.20) | 0.60 | 4.97 | 0.08
T-Score – Weighted Mean Difference | Unadjusted^†^ | 0.97 (0.18, 1.76) | 0.40 | 3.32 | 0.19
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.99 (0.21, 1.77) | 0.36 | 3.11 | 0.21
T-Score – Weighted Mean Difference | Common Set of Covariates | 0.91 (−0.24, 2.07) | 0.61 | 5.18 | 0.08
C-Score – Weighted Mean Difference | Unadjusted | 0.13 (0.03, 0.23) | 0.66 | 5.81 | 0.06
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.13 (0.03, 0.23) | 0.59 | 4.85 | 0.088
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.09 (−0.002, 0.19) | 0.55 | 4.43 | 0.11

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval

Appendix D. Table 12 Summary of traditional meta-analysis results for HUI cognition from CCHS-CLSA and Buschke total from CSHA and NuAge

Method of Statistical Harmonization | Adjustment | Summary Effect Estimate (95% CI) | I^2^ | Q^*^ | p-value
Raw Data – Using Hedge’s G | Unadjusted | 0.10 (−0.05, 0.24) | 0.80 | 9.76 | 0.008
Raw Data – Using Hedge’s G | Unadjusted (Including Participants with Complete Data for Covariates) | 0.10 (−0.05, 0.24) | 0.77 | 8.65 | 0.01
Raw Data – Using Hedge’s G | Study-Specific Statistically Significant Covariates | 0.08 (−0.05, 0.21) | 0.73 | 7.32 | 0.03
Raw Data – Using Hedge’s G | Common Set of Covariates | 0.08 (−0.04, 0.20) | 0.67 | 6.10 | 0.047
T-Score – Weighted Mean Difference | Unadjusted^†^ | 0.69 (−0.47, 1.84) | 0.69 | 6.49 | 0.04
T-Score – Weighted Mean Difference | Unadjusted^†^ (Including Participants with Complete Data for Covariates) | 0.71 (−0.44, 1.87) | 0.67 | 6.07 | 0.048
T-Score – Weighted Mean Difference | Common Set of Covariates | 0.81 (−0.48, 2.10) | 0.68 | 6.30 | 0.04
C-Score – Weighted Mean Difference | Unadjusted | 0.12 (−0.006, 0.24) | 0.74 | 7.73 | 0.02
C-Score – Weighted Mean Difference | Unadjusted (Including Participants with Complete Data for Covariates) | 0.12 (0.0001, 0.24) | 0.70 | 6.62 | 0.04
C-Score – Weighted Mean Difference | Common Set of Covariates | 0.10 (0.001, 0.20) | 0.53 | 4.28 | 0.12

* All Q Statistics have 2 degrees of freedom

† T-Scores minimally adjusted for age, sex and education level

Abbreviations: CI = confidence interval