# Distribution of Age, Sex, and Education Level for CCHS-CLSA, CSHA, and NuAge

Appendix C. Table 1 Age, Sex and Education Level Distribution of CCHS-CLSA, CSHA and NuAge Studies

Age group | Sex | Education level | CCHS-CLSA | | CSHA | | NuAge
Age group | Sex | Education level | Freq | % | Freq | % | Freq | %
65–69 | Male | Low (0–8) | 144 | 0.79 | 43 | 0.23 | 1 | 0.01
65–69 | Male | Medium (9–13) | 377 | 2.06 | 30 | 0.16 | 19 | 0.1
65–69 | Male | High (14+) | 578 | 3.15 | 5 | 0.03 | 22 | 0.12
65–69 | Female | Low (0–8) | 153 | 0.83 | 55 | 0.3 | 9 | 0.05
65–69 | Female | Medium (9–13) | 467 | 2.55 | 23 | 0.13 | 19 | 0.1
65–69 | Female | High (14+) | 658 | 3.59 | 7 | 0.04 | 15 | 0.08
70–74 | Male | Low (0–8) | 152 | 0.83 | 45 | 0.25 | 11 | 0.06
70–74 | Male | Medium (9–13) | 292 | 1.59 | 30 | 0.16 | 33 | 0.18
70–74 | Male | High (14+) | 353 | 1.93 | 9 | 0.05 | 49 | 0.27
70–74 | Female | Low (0–8) | 167 | 0.91 | 56 | 0.31 | 14 | 0.08
70–74 | Female | Medium (9–13) | 388 | 2.12 | 52 | 0.28 | 48 | 0.26
70–74 | Female | High (14+) | 402 | 2.19 | 10 | 0.05 | 25 | 0.14
75–79 | Male | Low (0–8) | 151 | 0.82 | 91 | 0.5 | 8 | 0.04
75–79 | Male | Medium (9–13) | 239 | 1.3 | 84 | 0.46 | 19 | 0.1
75–79 | Male | High (14+) | 259 | 1.41 | 30 | 0.16 | 21 | 0.11
75–79 | Female | Low (0–8) | 231 | 1.26 | 127 | 0.69 | 19 | 0.1
75–79 | Female | Medium (9–13) | 381 | 2.08 | 111 | 0.61 | 41 | 0.22
75–79 | Female | High (14+) | 368 | 2.01 | 35 | 0.19 | 21 | 0.11
80–84 | Male | Low (0–8) | 104 | 0.57 | 78 | 0.43 | 3 | 0.02
80–84 | Male | Medium (9–13) | 153 | 0.83 | 37 | 0.2 | 7 | 0.04
80–84 | Male | High (14+) | 121 | 0.66 | 13 | 0.07 | 7 | 0.04
80–84 | Female | Low (0–8) | 198 | 1.08 | 115 | 0.63 | 1 | 0.01
80–84 | Female | Medium (9–13) | 304 | 1.66 | 119 | 0.65 | 11 | 0.06
80–84 | Female | High (14+) | 260 | 1.42 | 31 | 0.17 | 9 | 0.05
85–89 | Male | Low (0–8) | 10 | 0.05 | 79 | 0.43
85–89 | Male | Medium (9–13) | 21 | 0.11 | 32 | 0.17
85–89 | Male | High (14+) | 24 | 0.13 | 13 | 0.07
85–89 | Female | Low (0–8) | 32 | 0.17 | 99 | 0.54
85–89 | Female | Medium (9–13) | 42 | 0.23 | 112 | 0.61
85–89 | Female | High (14+) | 32 | 0.17 | 28 | 0.15
90–94 | Male | Low (0–8) | | | 13 | 0.07
90–94 | Male | Medium (9–13) | | | 6 | 0.03
90–94 | Male | High (14+) | | | 4 | 0.02
90–94 | Female | Low (0–8) | | | 32 | 0.17
90–94 | Female | Medium (9–13) | | | 41 | 0.22
90–94 | Female | High (14+) | | | 5 | 0.03
95–99 | Male | Low (0–8) | | | 1 | 0.01
95–99 | Male | High (14+) | | | 1 | 0.01
95–99 | Female | Low (0–8) | | | 6 | 0.03
95–99 | Female | Medium (9–13) | | | 7 | 0.04
95–99 | Female | High (14+) | | | 3 | 0.02
100–104 | Female | Low (0–8) | | | 1 | 0.01

Abbreviations: CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study on Health and Aging; Freq = frequency; NuAge = Quebec Longitudinal Study on Nutrition and Aging

Appendix C Table 2 Standard Deviations of Cognitive Measures for Females Aged 70–74 and 75–79 with 9–13 Years of Education in CCHS-CLSA, CSHA and NuAge Studies

Study | Cognitive Measure | Standard Deviation 70–74 | Standard Deviation 75–79 | Min | Group
CCHS-CLSA | Rey | 1.85 | 1.78 | 1.78 | 75–79
CSHA | Rey | 1.94 | 2.05 | 1.94 | 70–74
CSHA | Buschke | 2.76 | 2.78 | 2.76 | 70–74
CSHA | Buschke Total | 2.16 | 1.72 | 1.72 | 75–79
NuAge | Buschke | 2.23 | 2.59 | 2.23 | 70–74
NuAge | Buschke Total | 1.37 | 2.18 | 1.37 | 70–74

Abbreviations: CCHS = Canadian Community Health Survey; CLSA = Canadian Longitudinal Study on Aging; CSHA = Canadian Study on Health and Aging; min = minimum; NuAge = Quebec Longitudinal Study on Nutrition and Aging