# Excluded Studies

Baujat B, Mahe C, Pignon JP, et al. A graphical method for exploring heterogeneity in meta-analyses: application to a meta-analysis of 65 trials. Stat Med. 2002;21(18):2641-52. [pmid: 12228882].
Cook KF, Teal CR, Bjorner JB, et al. IRT health outcomes data analysis project: an overview and summary. Qual Life Res. Suppl 1. 2007;16:121-32. [pmid: 17351824].
Kaplan RF, Trevino RP, Johnson GM, et al. Cognitive function in post-treatment Lyme disease: do additional antibiotics help?. Neurology. 2003;60(12):1916-22. [pmid: 12821733].
Koopman L, van der Heijden GJ, Glasziou PP, et al. A systematic review of analytical methods used to study subgroups in (individual patient data) meta-analyses. J Clin Epidemiol. 2007;60(10):1002-9. [pmid: 17884593].
Koopman L, van der Heijden GJ, Hoes AW, et al. Empirical comparison of subgroup effects in conventional and individual patient data meta-analyses. Int J Technol Assess Health Care. 2008;24(3):358-61. [pmid: 18601805].
Marston L, Carpenter JR, Walters KR, et al. Issues in multiple imputation of missing data for large general practice clinical databases. Pharmacoepidemiol Drug Saf. 2010;19(6):618-26. [pmid: 20306452].
Riley RD, Simmonds MC, Look MP. Evidence synthesis combining individual patient data and aggregate data: a systematic review identified current practice and possible methods. J Clin Epidemiol. 2007;60(5):431-9. [pmid: 17419953].
Riley RD. Commentary: like it and lump it? Meta-analysis using individual participant data. Int J Epidemiol. 2010;39(5):1359-61. [pmid: 20660642].
Thompson S, Kaptoge S, White I, et al. Statistical methods for the time-to-event analysis of individual participant data from multiple epidemiological studies. Int J Epidemiol. 2010;39(5):1345-59. [pmid: 20439481].
Zucker DR, Ruthazer R, Schmid CH. Individual (N-of-1) trials can be combined to give population comparative treatment effect estimates: methodologic considerations. J Clin Epidemiol. 2010;63(12):1312-23. [pmid: 20863658].