# References

1 Hawe P, Shiell A, Riley T. Complex interventions: how “out of control” can a randomised controlled trial be?. BMJ. 2004;328(7455):1561-3. [pmid: 15217878].
2 Medical Research Council. A framework for development and evaluation of RCTs for complex interventions to improve health. London. Medical Research Council. 2000:1.
3 Craig P, Dieppe P, Macintyre S, et al. Developing and evaluating complex interventions: the new Medical Research Council guidance. BMJ. 2008;337:a1655. [pmid: 18824488].
4 Pawson R, Greenhalgh T, Harvey G, et al. Realist review—a new method of systematic review designed for complex policy interventions. J Health Serv Res Policy. 2005;10(Suppl 1):21-34. [pmid: 16053581].
5 Alexander JA, Hearld LR. What can we learn from quality improvement research? A critical review of research methods. Med Care Res Rev. 2009;66(3):235-71. [pmid: 19176833].
6 Higgins J, Green S. Cochrane handbook for systematic reviews of interventions, version 5.1.0. Updated March 2011. The Cochrane Collaboration. 2011.
7 Carr S, Lhussier M, Forster N, et al. An evidence synthesis of qualitative and quantitative research on component intervention techniques, effectiveness, cost-effectiveness, equity and acceptability of different versions of health-related lifestyle advisor role in improving health. Health Technology Assessment. 2011;15(9).
8 Michael Y, Whitlock E, Lin J, et al. Primary care- relevant interventions to prevent falling in older adults: a systematic evidence review for the US Preventive Services Task Force. Ann Int Med. 2010;153(12):815-25. [pmid: 21173416].
9 Raman G, DeVine D, Lau J. Non-pharmacological interventions for post-discharge care in heart failure patients. Agency for Healthcare Research and Quality. Rockville, MD. 2008.
10 Bower P, Gilbody S, Richards D, et al. Collaborative care for depression in primary care. Making sense of a complex intervention: systematic review and meta-regression. Br J Psychiatry. 2006;189:484-93. [pmid: 17139031].
11 Lin JS, Whitlock EP, Eckstrom E, et al. Challenges in Synthesizing and Interpreting the Evidence From a Systematic Review of Multifactorial Interventions to Prevent Functional Decline in Older Adults. Agency for Healthcare Research and Quality. Rockville, MD. 2012. http://www.ncbi.nlm.nih.gov/books/NBK114219/pdf/TOC.pdf.
12 Jackson N, Waters E. Guidelines for Systematic Reviews in Health Promotion and Public Health Taskforce. Criteria for the systematic review of health promotion and public health interventions. Health Promot Int. 2005;20(4):367-74. [pmid: 16169885].
13 Takeda A, Taylor S, Taylor R, et al. Clinical service organisation for heart failure. The Cochrane Collaboration. CD002752. 2012.
14 Thomas J, Sutcliffe K, Harden A, et al. Children and healthy eating: a systematic review of barriers and facilitators. EPPI-Centre, Institute of Education, University of London. 2003.
15 Avellar S, Paulsell D. Lessons learned from the home visiting evidence of effectiveness review. U.S. Department of Health and Human Services. 2011.
16 Smetana GW, Landon BE, Bindman AB, et al. A comparison of outcomes resulting from generalist vs specialist care for a single discrete medical condition: a systematic review and methodologic critique. Arch Intern Med. 2007;167(1):10-20. [pmid: 17210873].
17 Rycroft-Malone J, McCormack B, Hutchinson AM, et al. Realist synthesis: illustrating the method for implementation research. Implement Sci. 2012;7(1):33. [pmid: 22515663].
18 Crocker DD, Kinyota S, Dumitru GG, et al. Effectiveness of home-based, multi-trigger, multicomponent interventions with an environmental focus for reducing asthma morbidity: a community guide systematic review. Am J Prev Med. 2011;41(2):S5-S32. [pmid: 21767736].
19 Thygeson NM, Peikes D, Zutshi A. Mixed Methods: Fuzzy Set Qualitative Comparative Analysis and Configurational Comparative Methods: Powerful Methods to Study and Refine Patient-Centered Medical Home Models. AHRQ Publication No. 13-0026-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2013.
20 Centre for Reviews and Dissemination. Systematic reviews: CRD's guidance for undertaking reviews in health care. Centre for Reviews and Dissemination. 978-1-900640-47-3. Layerthorpe, York, UK. 2009. http://www.york.ac.uk/inst/crd/pdf/Systematic_Reviews.pdf.
21 Lenz M, Steckelberg A, Richter B, et al. Meta-analysis does not allow appraisal of complex interventions in diabetes and hypertension self-management: a methodological review. Diabetologia. 2007;50(7):1375-83. [pmid: 17520239].
22 Cochrane Effective Practice and Organization of Care Review Group. Data Collection Checklist. Ontario. Institute of Population Health; University of Ottawa. 2011.
23 Shepperd S, Lewin S, Straus S, et al. Can we systematically review studies that evaluate complex interventions?. PLoS Med. 2009;6(8):e1000086. [pmid: 19668360].
24 Moher D, Schulz K, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel group randomized trials. BMC Med Res Methodol. 2001;1(2). [pmid: 11336663].
25 Vandenbroucke J. The making of STROBE. Epidemiology. 2007;18(6):797-9. [pmid: 18049193].
26 Foy R, Ovretveit J, Shekelle PG, et al. The role of theory in research to develop and evaluate the implementation of patient safety practices. BMJ Qual Saf. 2011;20(5):453-9. [pmid: 21317181].
27 Glasziou P, Chalmers I, Altman D, et al. Taking healthcare interventions from trial to practice. BMJ. 2010;341:384-7. [pmid: 20709714].
28 Adam T, Hsu J, de Savigny D, et al. Evaluating health systems strengthening interventions in low-income and middle-income countries: are we asking the right questions?. Health Policy Plan. 2012;27(suppl 4):iv9-iv19. [pmid: 23014156].
29 Donabedian A. Evaluating the quality of medical care. Milbank Mem Fund Q. 1966;44(3):166-206. [pmid: 5338568].
30 Betts J. Aid Effectiveness and Governance Reforms: Applying realist principles to a complex synthesis across varied cases. Evaluation. 2013;19(3):249-68.
31 Anderson LM, Petticrew M, Rehfuess E, et al. Using logic models to capture complexity in systematic reviews. Research synthesis methods. 2011;2(1):33-42.
32 Bravata DM, McDonald KM, Shojania KG, et al. Challenges in systematic reviews: synthesis of topics related to the delivery, organization, and financing of health care. Ann Int Med. 2005;142(12 Pt 2):1056-65. [pmid: 15968030].
33 Dixon-Woods M, Agarwal S, Jones D, et al. Synthesising qualitative and quantitative evidence: a review of possible methods. J Health Serv Res Policy. 2005;10(1):45-53. [pmid: 15667704].
34 Greenhalgh T, Peacock R. Effectiveness and efficiency of search methods in systematic reviews of complex evidence: audit of primary sources. BMJ. 2005;331(7524):1064. [pmid: 16230312].
35 Ovretveit J. Evaluating Complex Social Interventions: Volume 1: challenges and choices, Volume 2: Guidance, tools and resources for researchers. CIPRS, Veterans Health Administration. 2013.
36 Victora CG, Habicht JP, Bryce J. Evidence-based public health: moving beyond randomized trials. Am J Public Health. 2004;94(3):400-5. [pmid: 14998803].
37 Glenton C, Lewin S, Mayhew A, et al. Nonrandomized studies are not always found even when selection criteria for health systems intervention reviews include them: a methodological study. J Clin Epidemiol. 2013;66(4):367-70. [pmid: 23380445].
38 Alexander JA, Hearld LR. Methods and metrics challenges of delivery-system research. Implement Sci. 2012;7(7):15-26. [pmid: 22409885].
39 Lewin S, Glenton C, Oxman AD. Use of qualitative methods alongside randomised controlled trials of complex healthcare interventions: methodological study. BMJ. 2009;339(b3496). [pmid: 19744976].
40 Renders CM, Valk GD, Franse LV, et al. Long-term effectiveness of a quality improvement program for patients with type 2 diabetes in general practice. Diabetes Care. 2001;24(8):1365-70. [pmid: 11473071].
41 Pineault R, Lamarche P, Beaulieu MD, et al. Conceptual and Methodological Challenges in Producing Research Syntheses for Decision-and Policy-Making: An Illustrative Case in Primary Healthcare. Evaluation. 2010;16(2):137-52.
42 Campbell M, Fitzpatrick R, Haines A, et al. Framework for design and evaluation of complex interventions to improve health. BMJ. 2000;321(7262):694. [pmid: 10987780].
43 Trikalinos T, Raman G, Kupelnick B, et al. Pulmonary rehabilitation for COPD and other lung diseases. Agency for Healthcare Research and Quality. Rockville, MD. 2006. http://www.cms.gov/Medicare/Coverage/DeterminationProcess/downloads/id43TA.pdf.
44 Cipriani A, Higgins JP, Geddes JR, et al. Conceptual and technical challenges in network meta-analysis. Ann Int Med. 2013;159(2):130-7. [pmid: 23856683].
45 Tricco AC, Ivers NM, Grimshaw JM, et al. Effectiveness of quality improvement strategies on the management of diabetes: a systematic review and meta-analysis. Lancet. 2012;379(9833):2252-61. [pmid: 22683130].
46 Equator Network. http://www.equator-network.org/2013.
47 Reflection Network. www.reflection-network.eu2013.
48 Davidson KW, Michael Goldstein M, Kaplan RM, et al. Evidence-based behavioral medicine: what is it and how do we achieve it?. Ann Behav Med. 2003;26(3):161-71. [pmid: 14644692].
49 Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials: The consort statement. JAMA. 1996;276(8):637-9. [pmid: 8773637].
50 Des Jarlais DC, Lyles C, Crepaz N. Improving the reporting quality of nonrandomized evaluations of behavioral and public health interventions: the TREND statement. Am J Public Health. 2004;94(3):361-6. [pmid: 14998794].
51 Boutron I, Moher D, Altman DG, et al. Extending the CONSORT statement to randomized trials of nonpharmacologic treatment: explanation and elaboration. Ann Int Med. 2008;148(4):295-309. [pmid: 18283207].
52 Ogrinc G, Mooney S, Estrada C, et al. The SQUIRE (Standards for QUality Improvement Reporting Excellence) guidelines for quality improvement reporting: explanation and elaboration. Qual Saf Health Care. 2008;17(Suppl 1):i13-i32. [pmid: 18836062].
53 Möhler R, Bartoszek G, Köpke S, et al. Proposed criteria for reporting the development and evaluation of complex interventions in healthcare (CReDECI): guideline development. Int J Nurs Stud. 2012;49(1):40-6. [pmid: 21924424].
54 Anderson L, Petticrew M, Chandler J, et al. Introducing a series of methodological articles on considering complexity in systematic reviews of interventions. J Clin Epidemiol. 2013. [pmid: 23953080].
55 Petticrew M, Anderson L, Elder R, et al. Complex interventions and their implications for systematic reviews: a pragmatic approach. J Clin Epidemiol. 2013. [pmid: 23953085].
56 Squires JE, Valentine JC, Grimshaw JM. Systematic reviews of complex interventions: framing the review question. J Clin Epidemiol. 2013. [pmid: 23953086].
57 Anderson L, Oliver S, Michie S, et al. Investigating complexity in systematic reviews of interventions by using a spectrum of methods. J Clin Epidemiol. 2013. [pmid: 23953087].
58 Petticrew M, Rehfuess E, Noyes J, et al. Synthesizing evidence on complex interventions: how meta-analytical, qualitative, and mixed-method approaches can contribute. J Clin Epidemiol. 2013. [pmid: 23953082].
59 Pigott T, Shepperd S. Identifying, documenting, and examining heterogeneity in systematic reviews of complex interventions. J Clin Epidemiol. 2013. [pmid: 23953079].
60 Burford B, Lewin S, Welch V, et al. Assessing the applicability of findings in systematic reviews of complex interventions can enhance the utility of reviews for decision making. J Clin Epidemiol. 2013. [pmid: 23953081].
61 Noyes J, Gough D, Lewin S, et al. A research and development agenda for systematic reviews that ask complex questions about complex interventions. J Clin Epidemiol. 2013. [pmid: 23953084].