# Methods

## Overview of the Approach

AHRQ charged a group of methodological thought leaders from EPCs and the Scientific Resource Center (SRC) to provide suggestions to EPCs on how to approach systematic reviews of complex multicomponent health care interventions for the EPC program.

Through biweekly workgroup calls, two in-person EPC meetings, a literature review, and key informant (KI) interviews of international thought leaders, the workgroup assembled best practices and developed a consensus methods white paper (Figure 1). Information was gathered through two complementary activities: a scan of the literature for publications about the methods of reviewing complex multicomponent interventions and interviews of researchers, systematic reviewers, and health systems leaders who have conducted reviews of complex multicomponent health systems interventions or who use reviews to guide their decision-making regarding implementation of multicomponent interventions.

Figure 1 Overview of the approach

A figure titled ‘Figure 1 Overview of the approach’. This figure outlines the methods and approach for the project. Along the top of the figure reads ‘Complex Multi-Component Intervention Methods Workgroup’. The figure contains two columns of four text boxes each. In each column, arrows point downward from each consecutive text box. An arrow points from the top left text box to the top right text box. Along the right side the text boxes read ‘Key Informant Interviews’, ‘Recruitment and Interview Guide Development’, ‘Key Informant Interviews’, ‘Qualitative Analysis of Interviews’. Along the left side the text boxes read ‘Literature Summary’, ‘Literature Identification’, ‘Literature Review’, ‘Literature Synthesis’. Along the bottom of the figure reads ‘Workgroup Synthesis & Consensus’ and arrows from the bottom two text boxes point to this text.

Individuals from five EPCs, the SRC, and AHRQ outlined the approach, set timelines, assigned and coordinated work, analyzed findings, and drafted and edited documents. All members participated in conference calls and assisted with development of the interview guide, literature review, and synthesis.

## Literature Summary

We searched Ovid Medline, Ovid EBM Reviews, and Cochrane Methodology Register, and performed a grey literature search to identify methodological papers about systematic reviews of complex multicomponent health care interventions, and, secondarily, to assemble examples of systematic reviews of such interventions. The latter exemplify challenges and approaches used by other systematic reviewers and are not intended to be comprehensive.

High value keywords were identified by committee members. A title/abstract keyword adjacency and subject search approach was utilized to identify relevant citations. The final search strategy appears in Appendix A.

To be eligible, methodological papers had to include an explicit statement in their abstract on methods for systematically reviewing complex/multicomponent interventions. Methods on any part of the systematic review process (e.g., searches, meta-analysis) were eligible.

Abstracts were dual reviewed by investigators using ABSTRACKR software (available at http://abstrackr.cebm.brown.edu). We reviewed the full text of included abstracts and abstracts that had discordant reviews. We also retrieved the full text of additional articles that were identified by workgroup members or KIs. Full-text articles were dual reviewed by investigators for inclusion (Table 1). We resolved conflicts about discordant reviews of full-text articles through discussion on workgroup calls.

Table 1 Inclusion/exclusion criteria

Include/Exclude | Reason
Include | Methods papers relating to systematic reviews of multicomponent interventions must be health, health care, or health systems focused: can be methods for any step in the systematic review process (for example, searching and analysis)
Include | Systematic reviews of multicomponent interventions: title or abstract indicates further thoughts addressing methodologic challenges
Exclude | Systematic reviews of multicomponent interventions that do not mention methodological issues in the title or abstract
Exclude | Foreign language
Exclude | Primary research study
Exclude | Paper focuses on specific health context or disease domain
Exclude | Paper is about mixed evidence synthesis or qualitative analysis but not specifically about complex multicomponent interventions
Exclude | Not relevant – other codes do not apply

## Key Informant Interviews

We invited 22 KIs to participate in a 90-minute individual or group interview between March 25 and April 26 of 2013. Each KI completed an “EPC Conflict of Interest Disclosure Form” prior to being interviewed and no disclosed conflicts precluded participation of any of the invited organizations. An interview guide was developed and used during the interviews. One investigator interviewed KIs about their experiences in analyzing, synthesizing, and reviewing complex interventions, and in identifying successful interventions, implementing them, and using reviews to assist in this process. All interviews were digitally recorded and transcribed and the transcripts were reviewed to identify and code themes. Transcripts were analyzed using content analysis using NVivo software by two objective research assistants with training in qualitative analyses. Narrative responses were reviewed as a whole to identify initial themes and then again in more detail to identify subthemes.

In addition to KI interviews, an exploratory discussion was held with members of the Community Forum Payer Panel. Themes from this discussion were identified by review of meeting summary notes.